# Executive Summary

## KEY FINDINGS

► We included 26 reviews of tai chi and qigong describing their effects on 21 health conditions in the evidence map. These conditions include breast cancer, cancer, chronic low back pain, chronic mechanical neck pain, chronic obstructive pulmonary disease, depression, diabetes, falls prevention, fibromyalgia, frailty in older adults, heart failure, hypertension, insomnia, knee osteoarthritis, mild cognitive impairment (cognitive function), osteoporosis, Parkinson’s disease (cognitive function), post-stroke, rheumatoid arthritis, sarcopenia, and schizophrenia.
► Two reviews concluded with high certainty of evidence that tai chi and qigong have a potential benefit for hypertension and osteoporosis.
► Evidence about adverse events was collected by 18 of 26 (69%) reviews, with most reviews reporting no serious adverse events. One review about tai chi and falls prevention did report moderate certainty of evidence for small harms from any adverse event.

Tai chi and qigong are popular and widely accepted complementary and integrative health (CIH) modalities for treatment of certain adult health conditions. Despite their popularity and long history in practice, evidence of beneficial effect of tai chi or qigong remains limited.

## METHODS

### Data Sources and Searches

Search strategies were developed in consultation with a medical librarian who is expert in literature reviews. We used a combination of MeSH keywords (eg, tai ji, qigong) and conducted searches from January 2014 to March 2024 in bibliographic databases (Allied and Complementary Medicine Database [AMED], Cumulated Index to Nursing and Allied Health Literature [CINAHL], Cochrane Database of Systematic Reviews [CDSR], Ovid MEDLINE, PsychINFO, and Scopus).

### Study Selection

Eligible publications were systematic reviews of studies that examined the efficacy or effectiveness of tai chi or qigong in adult health conditions. In general, any intervention described as “tai chi” or “qigong” was considered eligible; these included Traditional Chinese Exercises, mind-body exercise, baduanjin, etc. Studies were required to compare tai chi or qigong to a sham/placebo, usual care, or other active therapies (eg, exercise, health education, etc). An active therapy is defined as a therapy intended to have an intervention-specific effect that is not sham or placebo. Further details about the study selection process are described in the main report.

### Data Abstraction and Presentation

Each included systematic review had data abstracted by 1 reviewer and verified by a second reviewer. Abstracted data included number of studies included in the review that had tai chi or qigong as the intervention, treated condition, type of tai chi or qigong, comparators, certainty of evidence rating, and certainty of evidence conclusion(s) relevant to the effect of tai chi or qigong on an adult health condition. Our evidence mapping process resulted in a visual depiction of the evidence for tai chi and qigong, as well as an accompanying narrative with an ancillary figure and table.

## RESULTS

We identified 1,052 potentially relevant citations. A total of 460 publications were retained for further review and potential inclusion on the map. We included 26 publications (see ES Figure). In this map, bubble color denotes intervention type, shape denotes type of comparator, and size of shape indicates the number of primary studies included in the review.

ES Figure Evidence Map

*This review included distinct conclusions about separate conditions and comparators, and so it appears in this map more than once

Evidence map of conclusions from systematic reviews on tai chi and/or qigong. Reviews found either a potential benefit or no benefit compared to various comparison treatments, with varying levels of certainty in the evidence. Conclusions are categorized by certainty (high, moderate, low/very low) and visually coded by intervention type, comparator, and number of included studies.

Three high-level observations can be made from the evidence mapping process to suggest that there is a stronger evidence base for the potential benefit of tai chi or qigong for some adult health conditions since the last synthesis of literature.

1) Our update search identified 2 reviews describing conditions with high certainty of evidence and 16 reviews with moderate certainty of evidence of potential benefit of tai chi or qigong from reviews published since 2014. This is different from the last review, where tai chi or qigong had either no effect or unclear evidence of effect in most conditions.
2) More than half of the 15 conditions identified to have high or moderate certainty of evidence conclusions for benefit of tai chi and qigong had included more than 10 primary studies as the basis for their conclusions.
3) Every review compared tai chi or qigong with another active therapy comparator. There were conditions or topic areas included in the last evidence map that had included reviews that did not have information about comparators.

Evidence about adverse events was collected by 69% of the included reviews and no serious adverse events were reported. While 18 of 26 reviews mentioned adverse events, only 2 reviews included certainty of evidence conclusions for adverse events. One review about tai chi and falls prevention reported moderate certainty of evidence for small harms from any adverse event.

## DISCUSSION

### Key Findings

Our evidence map includes 26 new systematic reviews published since July 2014, and from these, 2 reviews reported high certainty of evidence and 16 reviews reported moderate certainty of evidence for beneficial effect of tai chi or qigong. While many of these conditions were also represented in the previous evidence map, our search identified reviews with higher certainty of evidence conclusions of effect of tai chi or qigong on several adult health conditions. This represents a stronger evidence base for the use of tai chi or qigong in health care settings since 2014.

### Future Research

Although more conclusions with high or moderate certainty of evidence were identified in the current search, signaling a stronger evidence base for tai chi or qigong, 21 conditions were represented by 26 reviews, indicating that the most critical research need is for more high-quality primary studies about tai chi or qigong to be conducted about a wider range of conditions. Moreover, it is critical to examine the effect of different styles of tai chi or qigong, as well as the effect of duration of practice. More research on long-term effects will also increase the evidence base for tai chi and qigong. For conditions of priority to the VA that currently do not have at least moderate-certainty evidence supporting use of tai chi or qigong, new studies that address limitations of existing research are needed.

### Conclusions

This evidence map about tai chi and qigong included reviews published since 2014 and showed that tai chi and qigong’s benefit on a few conditions is strong, but remains relatively sparse for others. More high-quality randomized controlled trials (RCT) are needed to provide an even stronger evidence base to assess the effect of tai chi and qigong on a wider range of adult health conditions.