# DISCUSSION

Our evidence map includes 26 systematic reviews published since January 2014, and from these, 2 reviews reported high certainty of evidence and 16 reviews reported moderate certainty of evidence for beneficial effect of tai chi or qigong. While many of these conditions were also represented in the previous evidence map, our search identified reviews with higher certainty of evidence conclusions of effect of tai chi or qigong on several adult health conditions. This represents a stronger evidence base for the use of tai chi or qigong in health care settings since 2014.

Strengths and Limitations

A strength of this evidence map compared to our prior map is that to be eligible for this map we required the authors of systematic reviews to formally assess the certainty (or strength) of their conclusions. Too many systematic reviews conclude with words to the effect that tai chi “may be an effective therapy for condition X, but more research is needed.” Such conclusions leave readers wondering how much certainty is contained in the word “may.” A strength of this map is that only reviews where certainty was formally assessed are included.

There are three main limitations. The first, common to all systematic reviews, is that we may not have identified all the potentially eligible evidence. If a systematic review was published in a journal not indexed in any of the 6 databases we searched, and we did not identify it as part of our search of references of included publications, then we would have missed it. Nevertheless, our search strategy did identify more than 450 publications about tai chi and qigong published since 2014, so we did not suffer from a lack of potential reviews to evaluate.

The second limitation, common to evidence maps, is that we did not independently reevaluate the primary studies included in eligible systematic reviews; in other words, we took the conclusions of the authors of included systematic reviews “at face value.” Particular to this application of the mapping process, for the health conditions that had more than 1 eligible review (ie, falls prevention, back pain), we only mapped the review we deemed most informative. This necessarily requires judgment, and others could disagree with that judgment. We included the citation for the review excluded from the map for this “overlap” reason in Appendix, and interested readers can review it for additional information. As in all evidence-based products, and particularly in one such as this covering a large and complex evidence base, it is possible that there are errors of data extraction and compilation. We used dual review to minimize the chance of such errors, but if we are notified of errors, we will correct them.

Lastly, readers should note that the interpretation of the effect of tai chi or qigong for some health conditions may be limited by certain patient characteristics in some instances. For example, in the case of osteoporosis, it would appear that many studies were conducted in China, with Asian women as the focus of these studies. Since Asian women have different bone turnover metabolisms compared to other racial group/ethnicities (e.g., Caucasian, Hispanic, African American), findings may not be applicable and therefore should be interpreted with these differences in mind. Another example is falls prevention, with respect to applicability of findings to specific populations (eg, healthy ambulatory older adults, higher risk fallers, Parkinson’s disease, stroke, mild cognitive impairment, older adults living in assisted living facilities).

## FUTURE RESEARCH

Although more conclusions with high or moderate certainty of evidence were identified in the current search, signaling a stronger evidence base for tai chi or qigong, 21 conditions were represented by 26 reviews, indicating that the most critical research need is for more high-quality primary studies about tai chi or qigong to be conducted about a wider range of conditions. For conditions of priority to the VA that currently do not have at least moderate-certainty evidence supporting use of tai chi or qigong, new studies that address limitations of existing research are needed.

More research on long-term effects will also increase the evidence base for tai chi and qigong. Moreover, it is critical to examine the effect of different styles of tai chi or qigong, as well as the effect of duration of practice. Since well-designed back-to-back comparisons of relative effectiveness of styles/forms are rare, it is unclear from the included reviews how readers are supposed to use or interpret findings in the context of style, and caution should be applied in interpreting statements of superiority of one form versus another. In addition, very few RCTs include formal protocols for systematically monitoring adverse events;^31^ thus, safety data should be interpreted cautiously. Future research should address these gaps.

## CONCLUSIONS

This evidence map about tai chi and qigong included reviews published since 2014 and showed that tai chi and qigong’s benefit on a few conditions is strong but remains relatively sparse for others. More high-quality randomized controlled trials are needed to provide an even stronger evidence base to assess the effect of tai chi and qigong on a wider range of adult health conditions.