# RESULTS

## LITERATURE FLOW DIAGRAM

The literature flow diagram summarizes the results of the study selection process. A full list of excluded studies is provided in the Appendix.

Literature flow diagram summarizing results of study selection process.

## OVERVIEW OF INCLUDED STUDIES

We identified 1,894 potentially relevant citations from database searches. After deduplicating these titles and including 11 titles recommended by experts, we had a total of 1,052 titles for initial screening (see Literature Flow Diagram). We applied the inclusion and exclusion criteria to these titles and abstracts and excluded 591 publications. We reviewed 460 publications at full-text stage. A total of 434 publications were excluded at this stage for the following reasons: not a systematic review (N = 37), did not formally assess the certainty or strength or quality of the evidence (N = 369), unable to distinguish effect for tai chi or qigong from other included interventions (N = 6), duplicate (N = 4), and not selected for map in favor of more informative review (N = 18). See Appendix for a full list of excluded reviews and a list of reviews not selected for the map by condition. We included 26 publications in this map. See Table 1 for more details about the included reviews.

Table 1 Characteristics of Included Studies

Author, Year Country | Condition (Outcome) | Intervention; Comparator; Number of Included Studies | Certainty of Evidence Rating | Certainty of Evidence Conclusion
Li, 2023^5^; China | Breast cancer (Disease-specific quality of life) | Tai chi; Sham, Active therapy/Usual care; 15 | Moderate | Compared to sham, active therapy, or usual care, “Tai chi Chuan-based exercise is helpful for improving QOL [quality of life], anxiety, and fatigue in patients with breast cancer.”
Ye, 2022^6^; China, Iran, USA | Breast cancer (Disease-specific quality of life) | Qigong; Active therapy/Usual care; 7 | Low/Very low | “Baduanjin is an effective exercise, which can significantly improve the quality of life and psychological health of breast cancer patients after operation.”
Sun, 2024^9^; China | Cancer (Anxiety) | Mixed tai chi/qigong; Active therapy/Usual care; 11 | Moderate | Compared to usual care or active therapy, “there was moderate certainty of evidence supporting the effect of tai chi/qigong on anxiety for adults with cancer.”
Ni, 2019^10^; China, Australia | Cancer (Disease-specific quality of life) | Tai chi; Sham, Active therapy/Usual care; 22 | Very low to moderate | “There is low-level evidence suggesting that Tai chi improves physical and mental dimensions of QOL [quality of life], and sleep. There is moderate-level evidence suggesting Tai chi reduces levels of cortisol...and improves limb function.”
Bower, 2024^11^; USA, Canada | Cancer-related fatigue | Mixed tai chi/qigong; Active therapy/Usual care; 5 | Moderate | Tai chi and qigong “showed significant improvement in fatigue scores as compared to conventional care, waitlist controls, or light exercise groups in patients with a variety of cancer types.”
Kang, 2024^12^; China | Chronic low back pain (Pain) | Tai chi; Active therapy/Usual care; 10 | Moderate | Compared to routine care and active therapy, “tai chi can reduce the pain degree of patients with low back pain.”
Kang, 2024^12^; China | Chronic low back pain (Disability) | Tai chi; Active therapy/Usual care; 4 | Low | Compared to routine care and active therapy, “tai chi can reduce the pain degree of patients with low back pain [and] improve the lumbar disability...Tai chi is a relatively safe choice for patients with low back pain.”
Gross, 2015^13^; USA, Canada, Netherlands | Chronic mechanical neck pain (Pain) | Qigong; Active therapy/Usual care; 2 | Moderate | “Qigong exercises (Dantian Qigong) may improve pain and function slightly when compared with a wait list control at immediate and short-term follow-up” among patients with chronic mechanical neck pain.
Ngai, 2016^14^; China, Australia, Singapore | Chronic obstructive pulmonary disease (Pulmonary function) | Tai chi; Active therapy/Usual care; 7 | Very low to moderate | “Evidence of very low to moderate quality suggests better functional capacity and pulmonary function in post-programme data for Tai chi versus usual care. When Tai chi in addition to other interventions was compared with other interventions alone, Tai chi did not show superiority and showed no additional effects on symptoms nor on physical and psychosocial function improvement in people with [chronic obstructive pulmonary disease].”
Noetel, 2024^7^; Australia, Spain, Denmark, Finland | Depression (Depressive symptoms) | Mixed tai chi/qigong; Active therapy/Usual care; 7 | Low/Very low | “Compared with active controls, ... moderate reductions in depression were found... for tai chi or qigong.”
Wu, 2023^15^; China | Diabetes (Blood glucose/lipid levels) | Tai chi; Active therapy/Usual care; 13 | Low/Very low | Compared to active therapy or usual care, “[Tai chi Chuan and Baduanjin] help to improve blood glucose and lipid levels in Type 2 Diabetes patients.”
Wu, 2023^15^; China | | Qigong; Active therapy/Usual care; 13 | Low/Very low | Compared to usual care, baduanjin helped improve blood glucose and lipid levels in patients with type 2 diabetes.
Pillay, 2024^16^; Canada | Falls prevention (Rate of falls) | Tai chi; Sham, Active therapy/Usual care; 16 | Moderate | Compared to sham, active therapy, or usual care, “long-duration tai chi interventions had some moderate certainty evidence [for benefit for falls].”
Skelly, 2020^8^; USA | Fibromyalgia (Pain) | Mixed tai chi/qigong; Active therapy/Usual care; 3 | Low/Very low | For fibromyalgia, “qigong and tai chi were associated with moderately greater improvement in pain (0–10 scale) compared with waitlist and an attention control in the short term...[There] is slight improvement in function for qigong compared with waitlist and a large improvement for tai chi compared with attention control.”
Buto, 2020^17^; Brazil | Frailty in older adults (Functional capacity/Quality of life) | Tai chi; Active therapy/Usual care; 8 | Low to moderate | Compared to active therapy or usual care, “a very low to moderate level of evidence was found regarding the effectiveness of Tai Chi in terms of functional capacity (balance, mobility, gait speed, functional reach and lower limb muscle strength) and a low level of evidence was found regarding its effect on quality of life...among prefrail and frail older adults.”
Chen, 2020^18^; China, Sweden | Heart failure (Disease-specific quality of life/Exercise capacity) | Tai chi; Active therapy/Usual care; 26 | Moderate | “Evidence from RCTs indicated (with a moderate level of certainty) that the addition of Tai chi and Qigong Practices into routine management was associated with a better quality of life, improved exercise capacity, increased [Left ventricular ejection fraction] (LVEF), and reduced [Brain natriuretic peptide] (BNP) level” as compared [with routine management alone]. Low evidence certainty showed that Tai chi and Qigong Practices were associated with a larger improvement in the quality of life and exercise capacity than general exercise.”
Ching, 2021^19^; Malaysia | Hypertension (Blood pressure) | Qigong; Active therapy/Usual care; 7 | Low/Very low | “Significant reductions in [blood pressure] is seen with the use of qigong as compared with the control group.”
Zhong, 2020^20^; China | Hypertension (Blood pressure) | Tai chi; Active therapy/Usual care; 9 | High | “The results demonstrated that Tai chi [versus active therapies] significantly reduced systolic blood pressure and diastolic blood pressure” in hypertensive patients.
Yang, 2023^21^; China | Insomnia (Sleep quality) | Tai chi; Active therapy/Usual care; 16 | Very low to moderate | “Tai chi exercise has a good preventive and ameliorating effect on insomnia, which can relieve patients’ depression and anxiety, simultaneously enhancing various functions of the body.”
Hu, 2021^22^; China | Knee osteoarthritis (Physical/Mental health) | Tai chi; Active therapy/Usual care; 16 | Low to moderate | “Tai chi exercise was beneficial for ameliorating physical and mental health of patients with knee osteoarthritis.”
Wang, 2022^23^; China | Mild Cognitive Impairment (Cognitive function) | Mixed tai chi/qigong; Active therapy/Usual care; 23 | Low/Very low | Compared to active therapy or usual care, “Tai chi and Qigong were effective interventions to improve cognition in patient with Parkinson’s Disease [and] mild cognitive impairment.”
Wang, 2022^23^; China | Parkinson’s Disease (Cognitive function) | Mixed tai chi/qigong; Active therapy/Usual care; 2 | Moderate | Compared to usual care or no intervention, tai chi or qigong had no effect on executive function of patients with Parkinson’s disease.
Liu, 2024^24^; China | Osteoporosis (Postmenopausal bone mineral density) | Mixed tai chi/qigong; Active therapy/Usual care; 32 | Moderate to high | Compared with usual care or drug therapy, “Traditional Chinese fitness exercises can significantly improve the bone mineral density levels of postmenopausal women.”
Su, 2024^25^; China, USA, Czech Republic, Greece | Post-stroke (Disease-specific quality of life) | Tai chi; Active therapy/Usual care; 6 | Low | Compared to usual care and active therapy, tai chi was “effective in improving quality of life for post-stroke patients.”
Su, 2024^25^; China, USA, Czech Republic, Greece | | Qigong; Active therapy/Usual care; 3 | Moderate | Compared to usual care and active therapy, qigong was “effective in improving quality of life for post-stroke patients.”
Lyu, 2021^26^; China | Post-stroke non-motor disorders (Cognitive/Sleep disorders) | Tai chi; Active therapy/Usual care; 6 | Low to moderate | “Tai chi may alleviate post-stroke depression in stroke survivors but has no clear effects on post-stroke cognitive and sleep disorders.”
Lyu, 2018^27^; China | Post-stroke rehabilitation (Functional movement) | Tai chi; Active therapy/Usual care; 21 | Low/Very low | “Tai chi has an overall beneficial effect on [activities of daily living], balance, limb motor function, and walking ability among stroke survivors, based on very low quality evidence, and may also improve sleep quality, mood, mental health, and other motor function.
Mudano, 2019^28^; USA, Canada | Rheumatoid arthritis (Pain/function) | Tai chi; Active therapy/Usual care; 7 | Low/Very low | “It is uncertain whether Tai chi has any effect on clinical outcomes (joint pain, activity limitation, function) in rheumatoid arthritis.”
Niu, 2022^29^; China | Sarcopenia (Muscle strength/Physical functioning) | Mixed tai chi/qigong; Active therapy/Usual care; 13 | Low to moderate | Tai chi and/or qigong “had a greater clinical effect in improving the severity of sarcopenia compared with no training or health education.”
Zheng, 2016^30^; China | Schizophrenia (Negative symptoms) | Tai chi; Active therapy/Usual care; 5 | Very low | Compared with active therapy, “Tai chi activity significantly improved negative symptoms” among patients with schizophrenia.
Zheng, 2016^30^; China | Schizophrenia (Positive symptoms) | Tai Chi; Active therapy/Usual care; 4 | Very low | Compared with active therapy, “Tai chi activity... had no obvious effects on positive symptoms” among patients with schizophrenia.

### Characteristics of Included Reviews

The number of primary studies about tai chi and qigong in the included reviews ranged from 2 studies to 32 studies. Four reviews included 2 to 5 studies,^8,11,13,30^ 9 reviews included 6 to 9 studies,^6,7,14,17,19,20,25,26,28^ and 13 reviews included more than 10 studies.^5,9,10,12,15,16,18,21–24,27,29^

The country of origin for reviews varied, with the largest number of reviews originating from China (N = 13),^5,9,12,15,20–24,26,27,29,30^ followed by the US (N = 1),^8^ Canada (N = 1),^16^ Brazil (N = 1),^17^ and Malaysia (N = 1).^19^ Nine reviews were conducted by authors from multiple countries: US and Canada (N = 2);^11,28^ China and Sweden;^18^ China and Australia;^10^ China, Australia, and Singapore;^14^ US, Canada, and the Netherlands;^13^ China, Iran, and US;^6^ China, US, Czech Republic, and Greece;^25^ and Australia, Spain, Denmark, and Finland.^7^

Of the 26 included reviews, 14 reviews were focused on tai chi only;^5,10,12,14,16–18,20–22,26–28,30^ 3 reviews about qigong only,^6,13,19^ of which 1 review was about baduanjin;^6^ and 7 reviews about tai chi and/or qigong (ie, outcomes reported together),^7–9,11,23,24,29^ of which 2 reviews were about traditional Chinese exercises.^24,29^ Two reviews about post-stroke disease-specific quality of life^25^ and diabetes^15^ reported outcomes for tai chi and qigong separately.

Every review included another active therapy as a comparator. Three reviews included sham in addition to active therapy/usual care as comparators.^5,10,16^ Examples of active therapy comparators included general exercises,^18^ health education,^20^and medication.^30^

Over half of the included reviews reported the length of the intervention, from 6 weeks to 96 weeks. About one-third of reviews reported the frequency of sessions, from once a week to 18 sessions per week. A few reviews reported the duration of sessions, from 15 minutes to 90 minutes per session. Several reviews included details about the style of tai chi. For example, a review about knee osteoarthritis reported, “Yang style tai chi (N = 7, 43.75%), Sun style tai chi (N = 3, 18.75%), tai chi qigong (N = 1, 6.25%) and ambiguous style tai chi (N = 5, 31.25%).”^22^ Another review about the effects of tai chi chuan (TCC) training on the disease-specific quality of life and psychological wellbeing in female patients with breast cancer reported that the “included RCTs were different types of TCC (Yang-style TCC, Chen-style TCC, 24-form simplified TCC, 20-form TCC, 18-form TCC, 8-form TCC, and Tai chi Cloud Hands).”^5^

The included 26 reviews were categorized into the following 21 health conditions: breast cancer,^5,6^ cancer outcomes,^9–11^ chronic low back pain,^12^ chronic mechanical neck pain,^13^ chronic obstructive pulmonary disease,^14^ depression,^7^ diabetes,^15^ falls prevention,^16^ fibromyalgia,^8^ frailty in older adults,^17^ heart failure,^18^ hypertension,^19,20^ insomnia,^21^ knee osteoarthritis,^22^ mild cognitive impairment (cognitive function),^23^ osteoporosis,^24^ Parkinson’s disease (cognitive function),^23^ post-stroke (non-motor disorders, rehabilitation, disease-specific quality of life),^25–27^ rheumatoid arthritis,^28^ sarcopenia,^29^ and schizophrenia.^30^

Five reviews were mapped more than once.^12,15,23,25,30^ Wang et al discussed the effect of tai chi or qigong on mild cognitive impairment as well as Parkinson’s disease.^23^ Diabetes was the focus of Wu et al’s review, and the authors reported outcomes for tai chi and qigong separately.^15^ Authors of a review about schizophrenia reported tai chi had a beneficial effect on negative symptoms, but found no difference for positive symptoms.^30^ Kang et al’s review about chronic low back pain reported tai chi had a beneficial effect on pain and disability.^12^ A review about post-stroke disease-specific quality of life reported outcomes for tai chi and qigong separately.^25^

We mapped conclusion(s) for the effect of tai chi or qigong on conditions that were also included in the previous evidence map: cancer, chronic mechanical neck pain, chronic obstructive pulmonary disease, dementia, depression, diabetes, falls prevention, hypertension, insomnia, muscle strength (ie, sarcopenia), osteoarthritis, osteoporosis, Parkinson’s disease, rheumatoid arthritis, and stroke rehabilitation (Table 2).

Table 2 Conditions or Topic Areas and Effects in 2014 and 2025 Evidence Maps

Condition (2014) | Effect (2014) | Condition (2025) | Effect (2025)
Chronic Obstructive Pulmonary Disease | Potential positive effect | Chronic Obstructive Pulmonary Disease | Potential benefit
Depression | Potential positive effect | Depression | Potential benefit
Falls - general | Potential positive effect | Falls prevention | Potential benefit
Hypertension | Potential positive effect | Hypertension | Potential benefit
Muscle strength | Potential positive effect | Sarcopenia (muscle strength); Sarcopenia (physical functioning) | No benefit; Potential benefit
Cancer | Unclear evidence | Cancer | Potential benefit
Dementia | Unclear evidence | Mild Cognitive Impairment - Cognitive function | Potential benefit
Fibromyalgia | Unclear evidence | Fibromyalgia | Potential benefit
Insomnia | Unclear evidence | Insomnia | Potential benefit
Osteoporosis | Unclear evidence | Osteoporosis | Potential benefit
Parkinson’s disease | Unclear evidence | Parkinson’s disease - cognitive function | No benefit
Rheumatoid arthritis | Unclear evidence | Rheumatoid arthritis | No benefit
Stroke rehabilitation | Unclear evidence | Post-stroke rehabilitation | Potential benefit
Diabetes | No effect | Diabetes | Potential benefit

We identified evidence for 11 new conditions in the updated search (Table 3).

Table 3 Newly Identified Conditions in 2025 Evidence Map

Condition | Effect
Breast cancer (disease-specific quality of life) | Potential benefit
Cancer (anxiety) | Potential benefit
Cancer-related fatigue | Potential benefit
Chronic low back pain (pain/disability) | Potential benefit
Chronic mechanical neck pain (pain) | Potential benefit
Frailty in older adults | Potential benefit
Heart failure (disease-specific quality of life/exercise capacity) | Potential benefit
Knee osteoarthritis (physical/mental health) | Potential benefit
Post-stroke (disease-specific quality of life) | Potential benefit
Post-stroke non-motor disorders (cognitive/sleep disorders) | No benefit
Schizophrenia (positive and negative symptoms) | No benefit

There were 18 conditions or topic areas in the previous evidence map that we did not identify evidence for in the 2025 evidence map (Table 4).

Table 4 Selected Conditions or Topic Areas in Previous Evidence Map Not in 2025 Evidence Map

Condition | Effect
Aerobic capacity | No effect
Life participation | No effect
Asthma | Unclear evidence
Cardiopulmonary | Unclear evidence
Cardiovascular disease | Unclear evidence
Chronic conditions | Unclear evidence
Cystic fibrosis | Unclear evidence
Health | Unclear evidence
Heart disease | Unclear evidence
Infections | Unclear evidence
Menopause | Unclear evidence
Metabolic syndrome | Unclear evidence
Multiple sclerosis | Unclear evidence
Pregnancy - anxiety | Unclear evidence
Psychological wellbeing | Unclear evidence
Post traumatic stress disorder | Unclear evidence
Urinary incontinence | Unclear evidence
Vestibulopathy | Unclear evidence

## EVIDENCE MAP

In the evidence map, columns correspond to whether a conclusion of the review was that 1) there was a potential benefit of tai chi or qigong relative to a comparison treatment, or 2) there was no benefit of tai chi or qigong relative to the comparison treatment. Columns are not mutually exclusive: a review could have more than 1 conclusion for separate comparators or type of tai chi or qigong, and those conclusions could differ in the potential benefit of tai chi or qigong.

Rows correspond to GRADE ratings of certainty of evidence:

- High certainty: We are very confident that the true effect lies close to that of the estimate of the effect.
- Moderate certainty: We are moderately confident in the effect estimate: the true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.
- Low certainty: Our confidence in the effect estimate is limited: the true effect may be substantially different from the estimate of the effect.
- Very low certainty: We have very little confidence in the effect estimate: the true effect is likely to be substantially different from the estimate of effect.

In contrast to columns, all rows are mutually exclusive. The top row indicates that at least 1 of the review’s conclusions about tai chi or qigong as rated by its authors has high (or strong) certainty of evidence. The middle row indicates that at least 1 of the review’s conclusions about tai chi or qigong was rated as moderate certainty of evidence (and none rated as high or strong, in which case it would be in the top row). The bottom row indicates that all of the review’s conclusions about tai chi or qigong were rated as low or very low certainty of evidence. Since GRADE assesses certainty of evidence, it is possible for a body of evidence to demonstrate low or moderate estimates of effect but with high certainty of evidence; conversely, it is possible to have evidence with large effect sizes but with low certainty.

Each conclusion is then mapped onto this framework and identified by the name of the condition, eg, “chronic low back pain,” “fibromyalgia,” “schizophrenia,” etc. Shapes are used to distinguish between the types of comparison treatments: circle for conclusions about comparisons to active therapy/usual care and triangle for conclusions about sham and active therapy/usual care. Colors are used to identify the conclusions specific to tai chi or qigong: blue for tai chi only, orange for qigong only (including baduanjin), and green for mixed tai chi and qigong (including Traditional Chinese Exercises).

The size of the bubble is used to indicate how many original research studies were included in the review about tai chi or qigong: the smallest bubble denotes reviews with 2–5 primary studies included, the medium bubble with a pattern of diagonal lines denotes reviews with 6–9 primary studies included, and the largest bubble denotes reviews with 10 or more primary studies included.

For example, in Figure 1, the medium-sized, blue open circle in the right column bottom row indicates that there is a review about rheumatoid arthritis that included 6 to 9 original studies and had a conclusion rated as low or very low certainty of evidence and that it is unclear whether tai chi has any effect on clinical outcomes for individuals with rheumatoid arthritis compared to active therapy or usual care. In the same figure, the large, green circle in the middle column of the middle row indicates a review about sarcopenia that included more than 10 original studies and had a conclusion rated as moderate certainty of evidence that tai chi and/or qigong were better than the comparison treatment of active therapy or usual care.

Figure 1. Evidence Map

*This review included distinct conclusions about separate conditions and comparators, and so it appears in this map more than once

Evidence map of conclusions from systematic reviews on tai chi and/or qigong. Reviews found either a potential benefit or no benefit compared to various comparison treatments, with varying levels of certainty in the evidence. Conclusions are categorized by certainty (high, moderate, low/very low) and visually coded by intervention type, comparator, and number of included studies.

There were 5 reviews with more than 1 conclusion about the effect of tai chi or qigong and they were mapped twice, denoted by an asterisk after the health condition.^12,15,23,25,30^

In addition to this map, we collected all certainty of evidence conclusions about tai chi or qigong in Table 5. There are 2 systematic reviews that described conditions (ie, osteoporosis,^24^ hypertension^20^) that had high certainty of evidence conclusions for the potential benefit of tai chi or qigong rated by the original review authors. There are 16 systematic reviews that described conditions that had moderate certainty of evidence conclusions for the potential benefit of tai chi or qigong rated by the original review authors.^5,9–14,16–18,21–23,25,26,29^ All remaining conclusions were judged by the original authors as being low or very low certainty of evidence, meaning, “Our confidence in the effect estimate is limited. The true effect may be substantially different from the estimate of effect” or “We have very little confidence in the effect estimate.”

Table 5 Certainty of Evidence Conclusions from Systematic Reviews Included in the Evidence Map

High Certainty of Evidence Conclusions (N = 2)
Author, Year | Condition | Certainty of Evidence Conclusion
Zhong, 2020^20^ | Hypertension | “The results demonstrated that Tai chi vs health education or no treatment...significantly reduced diastolic blood pressure” in hypertensive patients.
Liu, 2024^24^ | Osteoporosis | Compared to active therapy and usual care, “Traditional Chinese fitness exercises can significantly improve the bone mineral density levels of postmenopausal women.”
Moderate Certainty of Evidence Conclusions (N = 16)
Author, Year | Condition | Certainty of Evidence Conclusion
Li, 2023^5^ | Breast cancer (disease-specific quality of life) | Compared to sham, active therapy, or usual care, “Tai chi Chuan-based exercise is helpful for improving quality of life, anxiety, and fatigue in patients with breast cancer.”
Ni, 2019^10^ | Cancer (limb function) | Compared to sham, active therapy, and usual care, “there is moderate-level evidence suggesting Tai chi reduces levels of cortisol and improves limb function” among cancer survivors.
Sun, 2024^9^ | Cancer (anxiety) | Compared to usual care or active therapy, “there was moderate certainty of evidence supporting the effect of tai chi/qigong on anxiety for adults with cancer.”
Bower, 2024^11^ | Cancer-related fatigue | Tai chi and qigong “showed significant improvement in fatigue scores as compared to conventional care, waitlist controls, or light exercise groups in patients with a variety of cancer types.”
Kang, 2024^12^ | Chronic low back pain | Compared to routine care and active therapy, “tai chi can reduce the pain degree of patients with low back pain.”
Gross, 2015^13^ | Chronic mechanical neck pain | “Qigong exercises (Dantian Qigong) may improve pain and function slightly when compared with a wait list control at immediate and short-term follow-up” among patients with chronic mechanical neck pain.
Ngai, 2016^14^ | Chronic obstructive pulmonary disease | “Participants in the Tai chi group, when compared to those in the usual care alone group, may have showed better pulmonary function” among patients with chronic obstructive pulmonary disease.
Pillay, 2024^16^ | Falls prevention | Compared to sham, active therapy, or usual care, “long-duration tai chi interventions had some moderate certainty evidence [for benefit for falls prevention].”
Buto, 2020^17^ | Frailty in older adults (balance and mobility) | Compared to active therapy, “a moderate level of evidence related to the effectiveness of Tai chi in improving balance and mobility” among prefrail and frail older adults.
Chen, 2020^18^ | Heart failure (disease-specific quality of life) | Compared to active therapy, “the addition of Tai chi Qigong Practices was associated with a better quality of life, improved exercise capacity, increased [Left ventricular ejection fraction] (LVEF), and reduced [Brain natriuretic peptide] (BNP) level.”
Yang, 2023^21^ | Insomnia | “Tai chi exercise has a good preventive and ameliorating effect on insomnia, which can relieve patients’ depression and anxiety, simultaneously enhancing various functions of the body.”
Hu, 2021^22^ | Knee osteoarthritis | Compared to active therapies or usual care/no treatment, “tai chi exercise was beneficial for ameliorating physical and mental health of patients with knee osteoarthritis.”
Wang, 2022^23^ | Parkinson’s disease (cognitive function) | Compared to usual care or no intervention, “Tai chi and Qigong were effective interventions to improve cognition in patients with Parkinson’s disease.”
Su, 2024^25^ | Post-stroke (disease-specific quality of life) | Compared to usual care and active therapy, qigong was “effective in improving quality of life for post-stroke patients.”
Lyu, 2021^26^ | Post-stroke non-motor disorders | Compared to active therapy, “there were no differences between Tai chi and conventional rehabilitation therapy in terms of improvements in post-stroke mental disorders.”
Niu, 2022^29^ | Sarcopenia | Compared with no training or health education, “Traditional Chinese Exercises has no significantly greater clinical effects in improving grip strength, but had significantly greater clinical effects in physical function” among patients with sarcopenia.

Three high-level observations can be made from the evidence mapping process to suggest that there is a stronger evidence base for the potential benefit of tai chi or qigong for some adult health conditions since the last synthesis of literature.

First, our update search identified 2 reviews describing conditions with high certainty of evidence and 16 reviews with moderate certainty of evidence of potential benefit of tai chi or qigong from reviews published since 2014. This is different from the last review, where tai chi or qigong had either no effect or unclear evidence of effect in most conditions.

Reviews with high certainty of evidence conclusions are for osteoporosis (bone mineral density) and hypertension (blood pressure). Reviews with moderate certainty of evidence conclusions are for breast cancer (disease-specific quality of life), cancer (anxiety), cancer (limb function), cancer-related fatigue, chronic low back pain (pain), chronic mechanical neck pain (pain), chronic obstructive pulmonary disease (pulmonary function), cognition - Parkinson’s disease, falls prevention (rate of falls), frailty in older adults (balance and mobility), heart failure (disease-specific quality of life/exercise capacity), insomnia (sleep quality), knee osteoarthritis (physical/mental health), post-stroke (disease-specific quality of life), post-stroke non-motor disorders (cognitive/sleep disorders), and sarcopenia (physical functioning).

Second, more than half of the 15 conditions identified to have high or moderate certainty of evidence conclusions for benefit of tai chi and qigong ha d included more than 10 primary studies as the basis for their conclusions.

Third, every review compared tai chi or qigong with another active therapy comparator. There were conditions or topic areas included in the last evidence map that had included reviews that did not have information about comparators. Lack of information about comparators significantly limits the ability to adequately interpret the effect of an intervention.

### Adverse Events

Evidence about adverse events was collected by 18 of 26 (69%) reviews, with no serious adverse events reported. Two reviews included certainty of evidence for adverse events.^8,16^ The first review about falls prevention reported “moderate certainty for small harms (possibly 5–8 per 100 people) from any [adverse event], whereas there was low certainty for little-to-no harm for the more serious outcomes” in supervised, long-term group setting.^16^ Long term was defined in this review as “≥3 months or longer in duration.”^16^ The second review about fibromyalgia reported “2 adverse events (in 2 patients) judged to be possibly related to qigong practice: an increase in shoulder pain and plantar fasciitis” and “1 trial of tai chi reported no adverse events while the second trial reported that, across all intensities of tai chi versus aerobic exercise, there were no severe treatment-related adverse events and 5.3% (8/151) versus 5.3% (4/75) mild-moderate treatment-related adverse events.”^8^ Certainty of evidence for the first review was moderate and was insufficient for the second review.

Three other reviews provided additional details: One review about rheumatoid arthritis mentioned 2 primary studies provided “some narrative description of joint and muscle soreness and cramps; long-term adverse events were not reported.”^28^ Another review about knee osteoarthritis reported “only 2 studies reported minor muscle soreness and lower extremity pain in individual patients during the first days of tai chi exercise.”^22^ The third review about chronic mechanical neck pain provided details about adverse events “reported by 23 patients in qigong gr oup including: muscle soreness (N = 17), myogelosis (N = 12), vertigo (N = 10), other pain (N = 4), headache (N = 3), thirst (N = 1), engorged hands (N = 1), twinge in the neck (N = 1), urinary urgency (N = 1), bursitis of left shoulder (N = 1), nausea (N = 2), muscle tension (N = 1).”^13^