# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination from Juli Olson, DC, DACM, National Lead for Acupuncture, Integrative Health Coordinating Center; Alison Whitehead, MPH, C-IAYT, E-RYT200, National Lead, Integrative Health Coordinating Center; and Jonathan Loesch, BS, CTRS, National Tai Chi Lead for Integrative Health Coordinating Center. The scope was further developed with input from the topic nominator, the ESP Coordinating Center, and the review team. The scope of this report includes: 1) One or more evidence maps that provide a visual overview of the distribution of evidence for tai chi and qigong, and 2) an accompanying narrative that helps stakeholders interpret the state of the evidence to inform policy and clinical decision-making.

## KEY QUESTIONS AND ELIGIBILITY CRITERIA

The aim of this synthesis is to develop evidence maps that provide a visual overview of the distribution of evidence for tai chi and qigong on various adult health conditions, with accompanying narrative that helps stakeholders interpret the state of the evidence to inform policy and clinical decision-making.

## ELIGIBILITY CRITERIA

Study eligibility criteria are shown in the table below.

Domain | Eligibility Criteria
Population | Adults
Intervention | Tai chi or qigong
Comparator | Sham, active therapy/usual care/no treatment
Outcomes | Any
Study Design | Systematic reviews

## SEARCHING AND SCREENING

Search strategies were developed in consultation with a medical librarian who is expert in literature reviews. We used a combination of MeSH keywords (eg, tai ji, qigong) and conducted searches from January 2014 to March 2024 in bibliographic databases (Allied and Complementary Medicine Database [AMED], Cumulated Index to Nursing and Allied Health Literature [CINAHL], Cochrane Database of Systematic Reviews [CDSR], OvidMEDLINE, PsychINFO, Scopus) (see Appendix for complete search strategies).

Four reviewers independently screened titles and abstracts in duplicate, with any discrepancies resolved by group discussion. All titles and abstracts were selected based on the eligibility criteria described in the section below.

We next restricted eligibility to reviews that used formal methods to assess the certainty (or strength or quality) of the evidence for conclusions. In most reviews, this involved use of the Grading of Recommendations, Assessment, Development and Evaluations (GRADE) approach.^2^ However, other formal methods were accepted, such as the approach developed by the Agency for Healthcare Research & Quality (AHRQ) Evidence-based Practice Center (EPC) program^3^ and confidence in network meta-analysis (CINeMA).^4^ Certainty of evidence ratings assess the certainty or confidence in the estimates of the effect of an intervention:

- High certainty: We are very confident that the true effect lies close to that of the estimate of the effect.
- Moderate certainty: We are moderately confident in the effect estimate: the true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.
- Low certainty: Our confidence in the effect estimate is limited: the true effect may be substantially different from the estimate of the effect.
- Very low certainty: We have very little confidence in the effect estimate: the true effect is likely to be substantially different from the estimate of effect.

For example, a finding for benefit of an intervention with a very low certainty rating means it is not very likely that the evidence of benefit is the true effect. Conversely, a finding for benefit of an intervention with high certainty of evidence means it is very likely that the beneficial effect of the intervention is the true effect.

To remain eligible, a systematic review had to 1) state or cite the method used to formally assess the certainty (or strength or quality) of included evidence, and 2) report the certainty (or strength or quality) of evidence for the effect of tai chi or qigong on an adult health condition.

After applying this restriction, we abstracted health conditions. Any conditions with only a single eligible systematic review were included in the map: Cancer-related symptoms, chronic low back pain, chronic mechanical neck pain, chronic obstructive pulmonary disease, diabetes, falls prevention, fibromyalgia, hypertension, osteoarthritis, osteoporosis, post-stroke rehabilitation/non-motor outcomes, and sarcopenia were the health conditions with multiple reviews meeting eligibility criteria. For these conditions, we first assessed whether the review differed in some other feature used to classify reviews on our map. For example, 1 systematic review on disease-specific quality of life of women with breast cancer employed tai chi as intervention^5^ and a second review also about disease-specific quality of life of women with breast cancer employed qigong.^6^ In such cases, we included both reviews in the map, with the appropriate designations for the interventions. If there were multiple reviews on the same condition and they did not differ in some other feature, we mapped the review that was judged as being most informative to stakeholders. In general, this was the most recent review or the review with the greatest number of included studies. Systematic reviews otherwise meeting eligibility criteria that were not included in the map for this reason are listed in the Appendix.

## DATA ABSTRACTION

Each included systematic review had data abstracted by 1 reviewer and verified by a second reviewer. Abstracted data included number of studies included in the review that had tai chi or qigong as the intervention, treated condition, type of tai chi or qigong, comparators, certainty of evidence rating, and certainty of evidence conclusion(s) relevant to the effect of tai chi or qigong on an adult health condition.

## STUDY SELECTION

Eligible publications were systematic reviews of studies that examined the efficacy or effectiveness of tai chi or qigong in adult health conditions. In general, any intervention described as “tai chi” or “qigong” was considered eligible; these included Traditional Chinese Exercises, mind-body exercise, baduanjin.

Studies were required to compare tai chi or qigong to a sham/placebo, usual care, or other active therapies. An active therapy is defined as a therapy intended to have an intervention-specific effect that is not sham or placebo. Reviews that included studies of other interventions were eligible if results for tai chi or qigong were reported separately. Examples of such reviews are: Effect of Exercise for Depression: Systematic Review and Network Meta-Analysis of Randomized Controlled Trials^7^ or Noninvasive Nonpharmacological Treatment for Chronic Pain: A Systematic Review Update.^8^

## SYNTHESIS

Our evidence mapping process resulted in a visual depiction of the evidence for tai chi or qigong, as well as an accompanying narrative with an ancillary figure and table. The visual depiction or evidence map uses a bubble plot format to display information on 4 dimensions: bubble size, bubble label, x-axis, and y-axis. This allowed us to provide the following types of information about each included systematic review, as follows:

- Number of articles in systematic review (bubble size): The size of each bubble corresponds to the number of relevant primary research studies included in a systematic review. Relevant means studies contributing to the conclusions and certainty of evidence that were included on the map.
- Condition (bubble label): Each bubble is labeled with the condition discussed by that systematic review.
- Shapes and colors: Intervention characteristics for each condition are presented in the form of colors (type of intervention) and shapes (comparators). For type of intervention, blue for tai chi only, orange for qigong only, and green for mixed tai chi and qigong. Shapes are used to distinguish between the types of comparison treatments: circle for conclusions about comparisons to active therapy/usual care and triangle for conclusions about sham and active therapy/usual care.
- Strength of findings (rows): Each condition is plotted on the map based on the certainty of evidence statement as reported in the systematic review. We have 3 categories: “all conclusions are rated as low or very low certainty,” at least 1 conclusion is rated moderate certainty,” and “at least 1 conclusion is rated as high or strong certainty.”
- Effect of tai chi or qigong (columns): Each condition is plotted in either “potential benefit” or “no benefit” as effect of tai chi or qigong based on conclusion of systematic review.