# BACKGROUND

Tai chi (also “tai chi chuan,” “taijiquan,” or “taiji”) and qigong (also “baduanjin,” “yi jing jing,” “liu zi jue”) are mind-body exercises that originated from China. Tai chi and qigong have been part of Veterans’ standard medical benefits package under VHA Directive 1137.^1^ The VA internal SharePoint for tai chi and qigong includes these definitions:

○ “Tai Chi is a mind-body exercise combining slow-flowing intentional movements with breathing, awareness and visualization. Rooted in the Asian traditions of martial arts, Chinese medicine and philosophy, Tai chi enhances relaxation, vitality, focus, posture, balance, strength, flexibility, and mood.”
○ “Qigong is an ancient Chinese healing art, older than, and similar to tai chi, with a focus of cultivating the body’s vital energy or qi. It involves the coordination of the breath, posture, awareness, visualization and focused movements. Qigong may be a stationary or moving meditation.”

Interest in tai chi and qigong among Veterans has been growing, and this interest is expected to continue to grow as the VA continues to expand the program by hiring more instructors. An evidence map of research on tai chi and qigong published in 2014 was widely used to assist referring providers in their medical decision-making regarding when to offer tai chi or qigong for certain conditions or wellbeing. VHA’s Office of Patient Centered Care & Cultural Transformation, Integrative Health Coordinating Center was interested in new evidence since publication of the earlier map; thus, we conducted an update of the previous report and present a new evidence map of tai chi and qigong. Findings from this report will be used by VA referring providers, site leadership, and policy makers to improve Veteran access to non-pharmacologic treatment approaches and improve outcomes for Veterans by utilizing evidence-based care pathways.