# Appendices

## SEARCH STRATEGIES

Search Date: 03/21/24 | | Search Statement | Results
AMED | 1 | TI ((tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*)) OR AB ((tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*)) OR KW ((tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*)) | 549
AMED | 2 | TI ((qigong or qi gong or chi kung or ch’i kung or chigung or chi gung)) OR AB ((qigong or qi gong or chi kung or ch’i kung or chigung or chi gung)) OR KW ((qigong or qi gong or chi kung or ch’i kung or chigung or chi gung)) | 437
AMED | 3 | S1 or S2 | 896
AMED | 4 | CADTH CINAHL SR Filter – Removed MH and PT terms from beginning as they do not apply to this database | 11560
AMED | 5 | S3 and S4 | 153
AMED | 6 | limit S5 to 2014-Current | 122
CINAHL | 1 | (MH “Tai chi”) OR TI ((tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*)) OR AB ((tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*)) | 2944
CINAHL | 2 | (MH “Qigong”) OR TI ((qigong or qi gong or chi kung or ch’i kung or chigung or chi gung)) OR AB ((qigong or qi gong or chi kung or ch’i kung or chigung or chi gung)) | 1258
CINAHL | 3 | S1 or S2 | 3860
CINAHL | 4 | CADTH CINAHL SR Filter | 337253
CINAHL | 5 | S3 AND S4 | 698
CINAHL | 6 | limit 5 to 2014-Current | 523
Cochrane | 1 | MeSH descriptor: [Tai Ji] this term only | 577
Cochrane | 2 | (tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*):ti,ab,kw | 2036
Cochrane | 3 | MeSH descriptor: [Qigong] this term only | 150
Cochrane | 4 | (qigong or qi gong or chi kung or ch’i kung or chigung or chi gung):ti,ab,kw | 814
Cochrane | 5 | (or #1-#4) | 2701
Cochrane | 6 | limit #5 to reviews | 28
Cochrane | 7 | limit #6 to 2014-current | 22
Cochrane | 8
Cochrane | 9
Cochrane | 10
Ovid MEDLINE(R) Epub Ahead of Print and In-Process, In-Data-Review & Other Non-Indexed Citations; March 20, 2024 | 1 | Tai Ji/ or (tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*).ti,ab,kf. | 2849
Ovid MEDLINE(R) Epub Ahead of Print and In-Process, In-Data-Review & Other Non-Indexed Citations; March 20, 2024 | 2 | Qigong/ or (qigong or qi gong or chi kung or ch’i kung or chigung or chi gung).ti,ab,kf. | 1241
Ovid MEDLINE(R) Epub Ahead of Print and In-Process, In-Data-Review & Other Non-Indexed Citations; March 20, 2024 | 3 | 1 or 2 | 3682
Ovid MEDLINE(R) Epub Ahead of Print and In-Process, In-Data-Review & Other Non-Indexed Citations; March 20, 2024 | 4 | (systematic review or meta-analysis).pt. or meta-analysis/ or systematic review/ or systematic reviews as topic/ or meta-analysis as topic/ or “meta analysis (topic)”/ or “systematic review (topic)”/ or network meta-analysis/ or ((systematic* adj3 (review* or overview*)) or (methodologic* adj3 (review* or overview*)) or (quantitative adj3 (review* or overview* or synthes*)) or (research adj3 (integrati* or overview*)) or (integrative adj3 (review* or overview*)) or (collaborative adj3 (review* or overview*)) or (pool* adj3 analy*) or data synthes* or data extraction* or data abstraction* or handsearch* or hand search* or mantel haenszel or peto or der simonian or dersimonian or fixed effect* or latin square* or met analy* or metanaly* or technology assessment* or HTA or HTAs or technology overview* or technology appraisal* or meta regression* or metaregression* or (comparative adj3 (efficacy or effectiveness)) or (outcomes research or relative effectiveness) or ((indirect or indirect treatment or mixed-treatment or bayesian) adj3 comparison*) or (multi* adj3 treatment adj3 comparison*) or (mixed adj3 treatment adj3 (meta-analy* or metaanaly*)) or umbrella review* or (multi* adj2 paramet* adj2 evidence adj2 synthesis) or (multiparamet* adj2 evidence adj2 synthesis) or (multi-paramet* adj2 evidence adj2 synthesis)).ti,ab. or (meta-analysis or systematic review).md. or (meta-analy* or metaanaly* or systematic review* or biomedical technology assessment* or bio-medical technology assessment*).mp,hw. or (medline or cochrane or pubmed or medlars or embase or cinahl).ti,ab,hw. or (cochrane or (health adj2 technology assessment) or evidence report).jw. | 803047
Ovid MEDLINE(R) Epub Ahead of Print and In-Process, In-Data-Review & Other Non-Indexed Citations; March 20, 2024 | 5 | 3 and 4 | 971
Ovid MEDLINE(R) Epub Ahead of Print and In-Process, In-Data-Review & Other Non-Indexed Citations; March 20, 2024 | 6 | limit 5 to yr=”2014-Current” | 805
PsycINFO | 1 | (tai ji or tai chi or taiji or taijiquan or t’ai chi or t’ ai chi or shadowbox* or shadow box*).ti,ab. | 850
PsycINFO | 2 | (qigong or qi gong or chi kung or ch’i kung or chigung or chi gung).ti,ab. | 407
PsycINFO | 3 | 1 or 2 | 1125
PsycINFO | 4 | (systematic review or meta-analysis).pt. or meta-analysis/ or systematic review/ or systematic reviews as topic/ or meta-analysis as topic/ or “meta analysis (topic)”/ or “systematic review (topic)”/ or network meta-analysis/ or ((systematic* adj3 (review* or overview*)) or (methodologic* adj3 (review* or overview*)) or (quantitative adj3 (review* or overview* or synthes*)) or (research adj3 (integrati* or overview*)) or (integrative adj3 (review* or overview*)) or (collaborative adj3 (review* or overview*)) or (pool* adj3 analy*) or data synthes* or data extraction* or data abstraction* or handsearch* or hand search* or mantel haenszel or peto or der simonian or dersimonian or fixed effect* or latin square* or met analy* or metanaly* or technology assessment* or HTA or HTAs or technology overview* or technology appraisal* or meta regression* or metaregression* or (comparative adj3 (efficacy or effectiveness)) or (outcomes research or relative effectiveness) or ((indirect or indirect treatment or mixed-treatment or bayesian) adj3 comparison*) or (multi* adj3 treatment adj3 comparison*) or (mixed adj3 treatment adj3 (meta-analy* or metaanaly*)) or umbrella review* or (multi* adj2 paramet* adj2 evidence adj2 synthesis) or (multiparamet* adj2 evidence adj2 synthesis) or (multi-paramet* adj2 evidence adj2 synthesis)).ti,ab. or (meta-analysis or systematic review).md. or (meta-analy* or metaanaly* or systematic review* or biomedical technology assessment* or bio-medical technology assessment*).mp,hw. or (medline or cochrane or pubmed or medlars or embase or cinahl).ti,ab,hw. or (cochrane or (health adj2 technology assessment) or evidence report).jw. | 142962
PsycINFO | 5 | 3 and 4 | 179
PsycINFO | 6 | limit 5 to yr=”2014-Current” | 143
Scopus | 1 | TITLE-ABS-KEY (“tai ji” OR “tai chi” OR taiji OR taijiquan OR “t’ai chi” OR “t’ ai chi” OR shadowbox* OR “shadow box” OR “shadow boxing”) | 5690
Scopus | 2 | TITLE-ABS-KEY(qigong or “qi gong” or “chi kung” or “ch’i kung” or chigung or “chi gung”) | 2208
Scopus | 3 | 1 and 2 | 775
Scopus | 4 | CADTH Scopus SR Filter | 1268254
Scopus | 5 | 3 and 4 | 339
Scopus | 6 | limit 5 to 2014-Current | 307
| | Total | 1894
| | Total after deduplication | 1041

## STUDIES EXCLUDED DURING FULL-TEXT SCREENING

Citation | Exclude Reason
Cendoroglo, M. S. (2014). "Exercise programs for people with dementia." Sao Paulo medical journal = Revista paulista de medicina 132(3): 195–196.25272001 | Not a systematic review
Chang, W., W. Guo, R. Wang, X. Lin, S. Sun and Y. Shi (2021). "The effects on pain and disability of traditional Chinese non-pharmacological therapy for knee osteoarthritis: A protocol for systematic review and meta-analysis." Medicine 100(34): e27005.34449470 | Not a systematic review
Chen, G., Y. Lin, X. Zhao and B. Pu (2021). "Effects of Baduanjin on postoperative rehabilitation of patients with breast cancer: A protocol for systematic review and meta-analysis." Medicine 100(17): e25670.33907134 | Not a systematic review
Crew, A., J. Petrosky, K. Byrnes and R. Nelson (2015). "The Effects of Tai Chi on Physical Functioning in Older Adults with Parkinson’s Disease." Therapeutic Recreation Journal 49(1): 80–83. | Not a systematic review
Dai, W., X. Wang, R. Xie, M. Zhuang, X. Chang, G. Yang, J. Yu and L. Zhu (2020). "Baduanjin exercise for cervical spondylotic radiculopathy: A protocol for systematic review and meta-analysis." Medicine 99(18): e0037s.32358384 | Not a systematic review
de Sire, A., L. Lippi, N. Marotta, A. Folli, D. Calafiore, S. Moalli, A. Turco, A. Ammendolia, N. Fusco and M. Invernizzi (2023). "Impact of Physical Rehabilitation on Bone Biomarkers in Non-Metastatic Breast Cancer Women: A Systematic Review and Meta-Analysis." International Journal of Molecular Sciences 24(2). | Not a systematic review
Dong, X., R. Zhang, Y. Guo, L. Chen and Y. Liu (2020). "The efficacy of Qigong exercises for post-stroke mental disorders and sleep disorders: Protocol for a systematic review and meta-analysis." Medicine 99(34): e21784.32846809 | Not a systematic review
Gholamalishahi, S., C. Okechukwu, G. La Torre and A. Mannocci (2022). "Effects of Tai Chi and Qigong on fatigue and quality of life in patients with breast cancer: A narrative review of systematic reviews and meta-analyses." Cancer Research, Statistics, and Treatment 5(4): 685–691. | Not a systematic review
Grooten, W. J. A., C. Boström, Å. Dedering, M. Halvorsen, R. P. Kuster, L. Nilsson-Wikmar, C. B. Olsson, G. Rovner, E. Tseli and E. Rasmussen-Barr (2022). "Summarizing the effects of different exercise types in chronic low back pain – a systematic review of systematic reviews." BMC Musculoskeletal Disorders 23(1). | Not a systematic review
Guo, Y., M. Xu, M. Ji, J. Zhang, Q. Hu, Z. Wei, J. Yan, Y. Chen, J. Lyu, X. Shao, Y. Wang, J. Guo and Y. Wei (2018). "Effect of Liuzijue Qigong on patients with chronic obstructive pulmonary disease: Protocol for a systematic review and meta-analysis." Medicine 97(40): e12659.30290646 | Not a systematic review
Huston, P. and B. McFarlane (2016). "Health benefits of tai chi: What is the evidence?" Canadian family physician Medecin de famille canadien 62(11): 881–890.28661865 | Not a systematic review
Imoto, A. M., F. F. Amorim, H. Palma, I. Lombardi Junior, A. L. Salomon, M. S. Peccin, H. E. C. d. Silva, E. S. B. Franco, L. Gottems and L. A. Santana (2021). "Evidence for the efficacy of Tai Chi for treating rheumatoid arthritis: an overview of systematic reviews." Sao Paulo medical journal = Revista paulista de medicina 139(2): 91–97.33681883 | Not a systematic review
Jiang, L.-L., Y. Meng, Q. Zhang and W. Pan (2020). "Effect of Tai Chi on psychological disorder in college students: A protocol of systematic review and meta-analysis." Medicine 99(23): e20409.32501986 | Not a systematic review
Langhorst, J., P. Heldmann, P. Henningsen, K. Kopke, L. Krumbein, H. Lucius, A. Winkelmann, B. Wolf and W. Hauser (2017). "[Complementary and alternative procedures for fibromyalgia syndrome: Updated guidelines 2017 and overview of systematic review articles]." Komplementare und alternative Verfahren beim Fibromyalgiesyndrom: Aktualisierte Leitlinie 2017 und Ubersicht von systematischen Ubersichtsarbeiten. 31(3): 289–295. | Not a systematic review
Leung, Y. L. (2018). "Effects of Tai Chi exercise for community-dwelling Chinese adults with metabolic syndrome.DP - 2018." Dissertation Abstracts International: Section B: The Sciences and Engineering(1-B(E)): No-Pagination Specified. | Not a systematic review
Li, J., J. Guo, X. Wang, X. Zhang, Y. Zhang, M. Bu, X. Yao and Y. She (2023). "Efficacy and safety of tai chi exercise on bone health: An umbrella review." Osteoporosis international: a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA 34(11): 1853–1866.37430003 | Not a systematic review
Li, X., X. Wang, L. Song, J. Tian, X. Ma, Q. Mao, H. Lin and Y. Zhang (2020). "Effects of Qigong, Tai Chi, acupuncture, and Tuina on cancer-related fatigue for breast cancer patients: A protocol of systematic review and meta-analysis." Medicine 99(45): e23016.33157949 | Not a systematic review
Lorenc, A., P. Ronan, A. Mian, S. Madge, S. B. Carr, P. Agent and N. Robinson (2015). "Cystic fibrosis-Children and adults Tai Chi study (CF CATS2): Can Tai Chi improve symptoms and quality of life for people with cystic fibrosis? Second phase study protocol." Chinese journal of integrative medicine(101181180). | Not a systematic review
Luo, X.-C., J. Zhou, Y.-G. Zhang, Y.-Y. Liu, J.-J. Li, Z. Zheng, F. Tong and F. Feng (2020). "Effects of Tai Chi Yunshou on upper limb function and balance in stroke survivors: A protocol for systematic review and meta analysis." Medicine 99(29): e21040.32702844 | Not a systematic review
Negrini, F. (2021). "Is Tai Chi beneficial for rheumatoid arthritis?-A Cochrane Review summary with commentary." International journal of rheumatic diseases 24(6): 855–857.34097356 | Not a systematic review
Ng, C. A. C. M., N. Fairhall, G. Wallbank, A. Tiedemann, Z. A. Michaleff and C, Sherrington (2019). "Exercise for falls prevention in community-dwelling older adults: trial and participant characteristics, interventions and bias in clinical trials from a systematic review." BMJ open sport & exercise medicine 5(1): e000663. | Not a systematic review
Rasmussen-Barr, E., M. Halvorsen, T. Bohman, C. Boström, Å. Dedering, R. P. Kuster, C. B. Olsson, G. Rovner, E. Tseli, L. Nilsson-Wikmar and W. J. A. Grooten (2023). "Summarizing the effects of different exercise types in chronic neck pain – a systematic review and meta-analysis of systematic reviews." BMC Musculoskeletal Disorders 24(1). | Not a systematic review
Sawynok, J. and M. Lynch (2014). "Qigong and Fibromyalgia: Randomized Controlled Trials and Beyond." Evidence-based Complementary & Alternative Medicine (eCAM) 2014: 1–14. | Not a systematic review
Shi, H., C. Dong, H. Chang, L. Cui, M. Xia, W. Li, D. Wu, B. Yu, G. Si and T. Yang (2022). "Evidence Quality Assessment of Tai Chi Exercise Intervention in Cognitive Impairment: An Overview of Systematic Review and Meta-Analysis." Evidence-based complementary and alternative medicine: eCAM 2022(101215021): 5872847.35509627 | Not a systematic review
Shi, H., T. Liu, C. Dong, K. Zhen, Y. Wang, P. Liu, G. Si, L. Wang and M. Wang (2022). "Scientific Evidence of Traditional Chinese Exercise (Qigong) for Chronic Obstructive Pulmonary Disease: An Overview of Systematic Reviews and Meta-Analyses." BioMed research international 2022(101600173): 7728973.35958822 | Not a systematic review
Takemura, N., D. S. T. Cheung, D. Y. T. Fong, D. Hui, A. W. M. Lee, T. C. Lam, J. C. Ho, T. Y. Kam, J. Y. K. Chik and C. C. Lin (2024). "Tai Chi and Aerobic Exercise on Cancer-Related Dyspnea in Advanced Lung Cancer Patients: A Randomized Clinical Trial." J Pain Symptom Manage 68(2): 171–179.38729532 | Not a systematic review
Taylor, J. R. (2018). "The effects of Tai Chi compared to structured interventions on the Berg Balance Scale in older adults: A meta-analysis.DP - 2018." Dissertation Abstracts International: Section B: The Sciences and Engineering(10-B(E)): No-Pagination Specified. | Not a systematic review
Wang, F.-F., Y. Yuan, Y.-J. Song, Y.-Q. Wu, Y. He, X.-X. Deng, S.-L. Wu, D.-M. Dai and M. Wang (2020). "Exercise or sport activities for patients with cancer: A protocol for overview of systematic reviews and meta-analyses." Medicine 99(20): e20084.32443318 | Not a systematic review
Wang, H., J. Wang, M. Han and X. Niu (2023). "Quality assessment of systematic reviews assessing the effects of traditional Chinese exercises in the control of diabetes mellitus." Journal of Traditional Chinese Medical Sciences 10(3): 339–352. | Not a systematic review
Wu, C. and C. Tang (2019). "Reply to: Qigong as a promising mind-body exercise for cognitive functioning. [References].DP - Jul 2019." Journal of the American Geriatrics Society(7): 1534–1535.31026354 | Not a systematic review
Wu, H.-Y., Y.-R. Wang, G.-W. Wen, Z.-Y. Tang, Y.-Q. Yu, J.-R. Zhang, P. Liu and J.-H. Wu (2020). "Tai Chi on bone mineral density of postmenopausal osteoporosis: A protocol for systematic review and meta-analysis." Medicine 99(36): e21928.32899027 | Not a systematic review
Xia, T., Y. Yang, W. Li, Z. Tang, Z. Li and Y. Guo (2019). "The effect of meditative movement for glucose control in patients with type 2 diabetes A protocol for systematic review and meta-analysis of controlled trails." Medicine (United States) 98(19). | Not a systematic review
Yang, G. Y., J. Hunter, J. Liu, F. L. Bu, W. L. Hao and M. H. Zhang (2021). "Determining the safety and effectiveness of Tai Chi: A critical overview of 210 systematic reviews." Eur J Integr Med 48. | Not a systematic review
Yang, G.-Y., L.-Q. Wang, J. Ren, Y. Zhang, M.-L. Li, Y.-T. Zhu, J. Luo, Y.-J. Cheng, W.-Y. Li, P. M. Wayne and J.-P. Liu (2015). "Evidence base of clinical studies on Tai Chi: a bibliometric analysis." PloS one 10(3): e0120655.25775125 | Not a systematic review
Yu, P., W. Li, H. Li, S. Ouyang, H. Cai, J. Wu, C. Tang and Q. Huang (2020). "The efficacy and safety of health qigong for anti-aging: Protocol for a systematic review and meta-analysis." Medicine 99(49): e22877.33285677 | Not a systematic review
Zhang, F., J. Zhao, N. Jiang, Q. Zhai, J. Hu and J. Zhang (2022). "Meta-Analysis of Tai Chi Chuan in Treating Lumbar Spondylosis and B ack Pain." Applied bionics and biomechanics 2022(101208624): 2759977.35178121 | Not a systematic review
Zhang, W., Y. Liu, J. Yu, D. Li, Y. Jia, Q. Zhang, Y. Gao, Z. Wan and W. Wei (2022). "Exercise improves sleep quality in older adults: A protocol for a systematic review and meta-analysis." BMJ Open 12(1). | Not a systematic review
Chen B-L, Guo J-B, Liu M-S, Effect of Traditional Chinese Exercise on Gait and Balance for Stroke: A Systematic Review and Meta-Analysis. PLoS ONE. 2015 2015;10(8):e0135932. AI 1.0. doi:10.1371/journal.pone.0135932 26291978 | Unable to distinguish effect for Tai chi or Qigong from other included interventions
Chen R, Guo Y, Kuang Y, Zhang Q. Effects of home-based exercise interventions on post-stroke depression: A systematic review and network meta-analysis. International Journal of Nursing Studies. 2024;152(gs8, 0400675):104698. doi:10.1016/j.ijnurstu.2024.104698 38290424 | Unable to distinguish effect for Tai chi or Qigong from other included interventions
Guo C-Y, Ma Y-J, Liu S-T, Traditional Chinese Medicine and Sarcopenia: A Systematic Review. Frontiers in aging neuroscience. 2022 2022;14(101525824):872233. AI 0.9. doi:10.3389/fnagi.2022.872233 35645784 | Unable to distinguish effect for Tai chi or Qigong from other included interventions
Kong L, Ren J, Fang S, Effects of traditional Chinese mind-body exercises for patients with chronic fatigue syndrome: A systematic review and meta-analysis. J glob health. 2023;13(101578780):04157. doi:10.7189/jogh.13.04157 37994837 | Unable to distinguish effect for Tai chi or Qigong from other included interventions
Wu Y-H-T, He W-B, Gao Y-Y, Han X-M. Effects of traditional Chinese exercises and general aerobic exercises on older adults with sleep disorders: A systematic review and meta-analysis. J integr med. 2021 2021;19(6):493–502. AI 1.0. doi:10.1016/j.joim.2021.09.007 34649821 | Unable to distinguish effect for Tai chi or Qigong from other included interventions
Zhang Y, Li C, Zou L, Liu X, Song W. The Effects of Mind-Body Exercise on Cognitive Performance in Elderly: A Systematic Review and Meta-Analysis. Int J Environ Res Public Health. 2018;15(12) doi:10.3390/ijerph15122791 | Unable to distinguish effect for Tai chi or Qigong from other included interventions
Chou R, Deyo R, Friedly J, Noninvasive Treatments for Low Back Pain. 2016 | Duplicate
Gross AR, Paquin JP, Dupont G, Exercises for mechanical neck disorders: A Cochrane review update. Manual Ther. 2016;24(9610924, dh3):25–45. doi:10.1016/j.math.2016.04.005 | Duplicate
Kay TM, Gross A, Goldsmith CH, Exercises for mechanical neck disorders. Cochrane Database of Systematic Reviews. 2015/01// 2015;(1):N.PAG–N.PAG. | Duplicate
Skelly, A. C., R. Chou, J. R. Dettori, J. A. Turner, J. L. Friedly, S. D. Rundell, R. Fu, E. D. Brodt, N. Wasson, C. Winter and A. J. R. Ferguson (2018). "Noninvasive Nonpharmacological Treatment for Chronic Pain: A Systematic Review." | Duplicate
Chau J, Leung L, Liu X, Effects of Tai chi on health outcomes among community-dwelling adults with or at risk of metabolic syndrome: A systematic review. Complement Ther Clin Pract. 2021/01/01/ 2021;44 | Not selected for map in favor of more informative review
Chou, R., R. Deyo, J. Friedly, A. Skelly, R. Hashimoto, M. Weimer, R. Fu, T. Dana, P. Kraegel, J. Griffin, S. Grusing and E. D. Brodt (2017). "Nonpharmacologic Therapies for Low Back Pain: A Systematic Review for an American College of Physicians Clinical Practice Guideline." Annals of internal medicine 166(7): 493–505.28192793 | Not selected for map in favor of more informative review
Dai L, Jiang Y, Wang P, Chen K. Effects of three traditional Chinese fitness exercises combined with antihypertensive drugs on patients with essential hypertension: A systematic review and network meta-analysis of randomized controlled trials. Evid Based Complement Alternat Med. 2021/01/01/ | Not selected for map in favor of more informative review
del-Pino-Cassado R, Obrero-Gaitan E, Lomas-Vega R. The effect of Tai chi on reducing the risk of falling: A systematic review, and meta-analysis. American Journal of Chinese Medicine. 2016/01/01/ 2016;44(5):895–906.27430918 | Not selected for map in favor of more informative review
Feng F, Luo X, Chen Y, Li J, Kang H, Yan B. Effects of Tai chi Yunshou on upper-limb function and balance in stroke survivors: A systematic review and meta-analysis. Complementary Therapies in Clinical Practice. 2023 2023;51(101225531):101741. doi:10.1016/j.ctcp.2023.101741 36868000 | Not selected for map in favor of more informative review
Hall A, Copsey B, Richmond H, Effectiveness of Tai chi for Chronic Musculoskeletal Pain Conditions: Updated Systematic Review and Meta-Analysis. Physical Therapy. 2017;97(2):227–238. doi:10.2522/ptj.20160246 27634919 | Not selected for map in favor of more informative review
Kuo C, Wang C, Chang W, Liao T, Chen P, Tung T. Clinical effects of Baduanjin qigong exercise on cancer patients: A systematic review and meta-analysis on randomized controlled trials. Evid Based Complement Alternat Med. 2021/01/01/ | Not selected for map in favor of more informative review
Liang H, Luo S, Chen X, Lu Y, Liu Z, Wei L. Effects of Tai chi exercise on cardiovascular disease risk factors and quality of life in adults with essential hypertension: A meta-analysis. Heart Lung. 2020;49(4):353–363. doi:10.1016/j.hrtlng.2020.02.041 32171586 | Not selected for map in favor of more informative review
Lomas-Vega R, Obrero-Gaitan E, Molina-Ortega FJ, Del-Pino-Casado R. Tai chi for Risk of Falls. A Meta-analysis. Journal of the American Geriatrics Society. 2017;65(9):2037–2043.28736853 | Not selected for map in favor of more informative review
Shao B, Zhang X, Vernooij R, The effectiveness of Baduanjin exercise for hypertension: a systematic review and meta-analysis of randomized controlled trials. BMC Complement Med Ther. 2020;20(1):304. doi:10.1186/s12906-020-03098-w 33032580 | Not selected for map in favor of more informative review
Sherrington, C., N. Fairhall, W. Kwok, G. Wallbank, A. Tiedemann, Z. A. Michaleff, C. A. C. M. Ng and A. Bauman (2020). "Evidence on physical activity and falls prevention for people aged 65+ years: systematic review to inform the WHO guidelines on physical activity and sedentary behaviour." The international journal of behavioral nutrition and physical activity 17(1): 144.33239019 | Not selected for map in favor of more informative review
Sun Z, Chen H, Berger MR, Zhang L, Guo H, Huang Y. Effects of tai chi exercise on bone health in perimenopausal and postmenopausal women: a systematic review and meta-analysis. Osteoporos Int. 2016;27(10):2901–11. doi:10.1007/s00198-016-3626-3 27216996 | Not selected for map in favor of more informative review
Winser S, Kannan P, Krishnamurthy K, Tsang W. Tai chi for Balance and Falls Incidence in Neurological Disorders: A Systematic Review and Meta-Analysis. Archives of Physical Medicine & Rehabilitation. 2017/10// 2017;98(10):e134–e134. doi:10.1016/j.apmr.2017.08.437 | Not selected for map in favor of more informative review
Winser SJ, Tsang WW, Krishnamurthy K, Kannan P. Does Tai chi improve balance and reduce falls incidence in neurological disorders? A systematic review and meta-analysis. Clinical rehabilitation. 2018;32(9):1157–1168. doi:10.1177/0269215518773442 29737198 | Not selected for map in favor of more informative review
Wu Y, Johnson BT, Chen S, Chen Y, Livingston J, Pescatello LS. Tai Ji Quan as antihypertensive lifestyle therapy: A systematic review and meta-analysis. J Sport Health Sci. 2021;10(2):211–221. doi:10.1016/j.jshs.2020.03.007 32360952 | Not selected for map in favor of more informative review
Zhang Q, Xu X, Wu Q, Effects of different traditional Chinese exercise in the treatment of essential hypertension: a systematic review and network meta-analysis. Front cardiovasc med. 2024;11(101653388):1300319. doi:10.3389/fcvm.2024.1300319 38481952 | Not selected for map in favor of more informative review
Zhang Y, Chai Y, Pan X, Shen H, Wei X, Xie Y. Tai chi for treating osteopenia and primary osteoporosis: a meta-analysis and trial sequential analysis. Clin Interv Aging. 2019;14(101273480):91–104. doi:10.2147/CIA.S187588 30655662 | Not selected for map in favor of more informative review
Zhao J, Chau JPC, Lo SHS, Choi KC, Liang S. The effects of sitting Tai chi on physical and psychosocial health outcomes among individuals with impaired physical mobility: A systematic review and meta-analysis. International Journal of Nursing Studies. 2021;118(gs8, 0400675):103911. doi:10.1016/j.ijnurstu.2021.103911 33751992 | Not selected for map in favor of more informative review

## REVIEWS MEETING ELIGIBILITY CRITERIA BUT NOT INCLUDED IN EVIDENCE MAP IN FAVOR OF A MORE INFORMATIVE REVIEW

Citation | Condition
Hall A, Copsey B, Richmond H, Effectiveness of Tai chi for Chronic Musculoskeletal Pain Conditions: Updated Systematic Review and Meta-Analysis. Physical Therapy. 2017;97(2):227–238. doi:10.2522/ptj.20160246 27634919 | Back pain
Kuo C, Wang C, Chang W, Liao T, Chen P, Tung T. Clinical effects of Baduanjin qigong exercise on cancer patients: A systematic review and meta-analysis on randomized controlled trials. Evid Based Complement Alternat Med. 2021/01/01/ | Cancer-related symptoms/fatigue
Chou, R., R. Deyo, J. Friedly, A. Skelly, R. Hashimoto, M. Weimer, R. Fu, T. Dana, P. Kraegel, J. Griffin, S. Grusing and E. D. Brodt (2017). "Nonpharmacologic Therapies for Low Back Pain: A Systematic Review for an American College of Physicians Clinical Practice Guideline." Annals of internal medicine 166(7): 493–505.28192793 | Chronic low back pain
Zhao J, Chau JPC, Lo SHS, Choi KC, Liang S. The effects of sitting Tai chi on physical and psychosocial health outcomes among individuals with impaired physical mobility: A systematic review and meta-analysis. International Journal of Nursing Studies. 2021;118(gs8, 0400675):103911. doi:10.1016/j.ijnurstu.2021.103911 33751992 | Depression
del-Pino-Cassado R, Obrero-Gaitan E, Lomas-Vega R. The effect of Tai chi on reducing the risk of falling: A systematic review, and meta-analysis. American Journal of Chinese Medicine. 2016/01/01/ 2016;44(5):895–906.27430918 | Falls prevention
Lomas-Vega R, Obrero-Gaitan E, Molina-Ortega FJ, Del-Pino-Casado R. Tai chi for Risk of Falls. A Meta-analysis. Journal of the American Geriatrics Society. 2017;65(9):2037–2043.28736853 | Falls prevention
Sherrington, C., N. Fairhall, W. Kwok, G. Wallbank, A. Tiedemann, Z. A. Michaleff, C. A. C. M. Ng and A. Bauman (2020). "Evidence on physical activity and falls prevention for people aged 65+ years: systematic review to inform the WHO guidelines on physical activity and sedentary behaviour." The international journal of behavioral nutrition and physical activity 17(1): 144.33239019 | Falls prevention
Winser S, Kannan P, Krishnamurthy K, Tsang W. Tai chi for Balance and Falls Incidence in Neurological Disorders: A Systematic Review and Meta-Analysis. Archives of Physical Medicine & Rehabilitation. 2017/10// 2017;98(10):e134–e134. doi:10.1016/j.apmr.2017.08.437 | Falls prevention
Winser SJ, Tsang WW, Krishnamurthy K, Kannan P. Does Tai chi improve balance and reduce falls incidence in neurological disorders? A systematic review and meta-analysis. Clinical rehabilitation. 2018;32(9):1157–1168. doi:10.1177/0269215518773442 29737198 | Falls prevention
Chau J, Leung L, Liu X, Effects of Tai chi on health outcomes among community-dwelling adults with or at risk of metabolic syndrome: A systematic review. Complement Ther Clin Pract. 2021/01/01/ 2021;44 | Hypertension
Dai L, Jiang Y, Wang P, Chen K. Effects of three traditional Chinese fitness exercises combined with antihypertensive drugs on patients with essential hypertension: A systematic review and network meta-analysis of randomized controlled trials. Evid Based Complement Alternat Med. 2021/01/01/ | Hypertension
Liang H, Luo S, Chen X, Lu Y, Liu Z, Wei L. Effects of Tai chi exercise on cardiovascular disease risk factors and quality of life in adults with essential hypertension: A meta-analysis. Heart Lung. 2020;49(4):353–363. doi:10.1016/j.hrtlng.2020.02.041 32171586 | Hypertension
Shao B, Zhang X, Vernooij R, The effectiveness of Baduanjin exercise for hypertension: a systematic review and meta-analysis of randomized controlled trials. BMC Complement Med Ther. 2020;20(1):304. doi:10.1186/s12906-020-03098-w 33032580 | Hypertension
Wu Y, Johnson BT, Chen S, Chen Y, Livingston J, Pescatello LS. Tai Ji Quan as antihypertensive lifestyle therapy: A systematic review and meta-analysis. J Sport Health Sci. 2021;10(2):211–221. doi:10.1016/j.jshs.2020.03.007 32360952 | Hypertension
Zhang Q, Xu X, Wu Q, Effects of different traditional Chinese exercise in the treatment of essential hypertension: a systematic review and network meta-analysis. Front cardiovasc med. 2024;11(101653388):1300319. doi:10.3389/fcvm.2024.1300319 38481952 | Hypertension
Sun Z, Chen H, Berger MR, Zhang L, Guo H, Huang Y. Effects of tai chi exercise on bone health in perimenopausal and postmenopausal women: a systematic review and meta-analysis. Osteoporos Int. 2016;27(10):2901–11. doi:10.1007/s00198-016-3626-3 27216996 | Osteoporosis
Zhang Y, Chai Y, Pan X, Shen H, Wei X, Xie Y. Tai chi for treating osteopenia and primary osteoporosis: a meta-analysis and trial sequential analysis. Clin Interv Aging. 2019;14(101273480):91–104. doi:10.2147/CIA.S187588 30655662 | Osteoporosis
Feng F, Luo X, Chen Y, Li J, Kang H, Yan B. Effects of Tai chi Yunshou on upper-limb function and balance in stroke survivors: A systematic review and meta-analysis. Complementary Therapies in Clinical Practice. 2023 2023;51(101225531):101741. doi:10.1016/j.ctcp.2023.101741 36868000 | Post-stroke rehabilitation//non-motor outcome

## PEER REVIEW COMMENTS AND RESPONSES

Are the objectives, scope, and methods for this review clearly described?
Comment # | Reviewer # | Comment | Author Response
1 | 1 | Yes | Thank you.
2 | 2 | Yes | Thank you.
3 | 3 | Yes | Thank you.
4 | 4 | Yes | Thank you.
5 | 5 | No - Page 9 Overview of Included Studies—not sufficient explanation; Unclear methods for determining why the 22 were “not selected for map in favor of better review (N = 22)”. Line 14–15 What was the criteria for ‘better review.’ This is a large number, equal to the N of the included studies, so it is necessary to understand why half of the studies were excluded.; Vast majority of studies 362 were excluded for: “Did not grade evidence” Page 8 flow diagram and Page 9, Line 9 “..did not include the method used to formally assess the certainty or strength or quality of the evidence.” Would be helpful to better understand this criteria and provide further details on this determination since it seems a significant proportion of the literature was excluded at this stage (~85%). | We have clarified that the criteria for selecting the more informative review included when the search was completed (ie, how up to date was the review is), and how many primary studies were included. We have also described the GRADE system and how we assessed whether it or something similar was used to grade evidence.
6 | 5 | Another 40–50 systematic reviews appear to have been either missed or otherwise not included in the evidence map. This requires more explanation of criteria used to exclude—I believe many appear to be eligible for inclusion. Please see list below. | Of the 70 reviews suggested by reviewer #4 and #5, we have examined in detail all of the 70 publications. Of these 70, 1 review was actually included on the map; it must have been inadvertently overlooked by the reviewer;1 was published before the current review’s search dates and was excluded because it did not grade evidence; 1 was excluded at title screening, 6 were excluded at abstracts screening (not a systematic review=2, outcomes for tai chi/qigong were not reported separately=4); 50 were excluded because they did not formally rate the certainty of evidence, which was an inclusion criterion; 2 were not in journals indexed in PubMed or did not use any indexing terms we searched on; and 9 we could not have found in our search because they were published after the end date of that search. We reviewed all 9 and excluded 4 publications, because they did not formally assess the certainty of the evidence. For the remaining 5, 1 was excluded for being a randomized controlled trial; 2 reviews were more recent, and more informative, than reviews already included on the map for chronic low back pain and falls prevention. We replaced these as included reviews. The certainty of evidence for the review about falls prevention remain moderate, but certainty of evidence for chronic low back pain has advanced from low to moderate. Lastly, we added 2 reviews to the map, one about cancer related fatigue and the second about anxiety.
7 | 7 | Yes | Thank you.
8 | 8 | Yes | Thank you.
Is there any indication of bias in our synthesis of the evidence?
Comment # | Reviewer # | Comment | Author Response
9 | 1 | No | Thank you.
10 | 2 | No | Thank you.
11 | 3 | No | Thank you.
12 | 4 | No | Thank you.
13 | 5 | No | Thank you.
14 | 7 | No | Thank you.
15 | 8 | No | Thank you.
Are there any published or unpublished studies that we may have overlooked?
Comment # | Reviewer # | Comment | Author Response
16 | 1 | Yes - Conclusions on Falls does not take into account multiple large scale trials, only some of which are including in now dated Sherrington Review.; This review should probably cite in Discussion recent parallel attempts to synthesize state of tai chi evidence (e.g. Yang GY et al 2022 SR of 200+ SRs on Tai Chi), and perhaps discuss how your finding compare. | Because the Yang et al. publication is a review of reviews, and not a hybrid of reviews plus new evidence, a more recent publication which might have included multiple large-scale trials, would only be included in this report if the review graded evidence (ie, certainty or strength of evidence). There may have been newer and larger reviews about falls prevention but if these reviews did not include certainty of evidence rating, we would have excluded these reviews. A review published after our search date was suggested and we have included this newer review on the map (Pillay 2024).
17 | 2 | No | Thank you.
18 | 3 | No | Thank you.
19 | 4 | Yes - TO: VA Evidence Synthesis Program; RE: Review of Tai Chi Qiqong for Health and Well-being.; Thank you for the opportunity to review this Tai Chi and Qigong VA systematic review. I truly believe that Tai Chi and Qigong are evidence-based medicine for the 21st century. | Thank you for your comments.
20 | 4 | I have clustered my feedback leading with RE: headings for various topics.; RE: Bubble maps (Figure 2) and search strategies; Your previous rendition of the VA evidence map was much easier to read. I agree that the use of circles of different diameters is a great way to reveal number of articles for different topics (conditions).; However, the use of 5 areas of evaluation and multiple colors/symbols makes reading the figure time intensive, rendering this evidence map much harder to quickly interpret. I would consider using format used in prior renditions OR if needed separate tai chi, qigong and others more distinctly, through a series of evidence bubbles by category of intervention. | Regarding the map, we have reduced the number of interventions to tai chi only, qigong only, and mix of tai chi and qigong. With fewer colors, it may improve readability of the map.; We have also reordered the bubbles so that all tai chi only reviews are grouped together, all qigong are grouped together, and all mixed reviews are grouped together. Since our VA operational partners had requested an evidence map of tai chi and qigong, it would be best to keep both tai chi and qigong reviews on the same map.
21 | 4 | It is my understanding that Qi gong, translated ‘energy cultivation’ is the larger umbrella term of which the other practices fall under. For this reason, ‘qigong’ literature is always more-broad, i.e., less homogeneous than say, ‘Yang-style Tai Chi.’ Does merging these two categories detract from analysis (or at least render it more difficult). | The scope of the project was determined in consultation with Operational Partners in the VA with expertise in the topic. It is under their direction that tai chi and qigong literature were reviewed in the same project. Since the purpose of this evidence map is to identify body of evidence for tai chi and/or qigong, merging these two categories did not detract from the current analysis.
22 | 4 | RE: Literature Review Process; Regarding the articles you excluded in this review, for the most part I think your team did very well. It seems reasonable that several excluded items were from before 2020 (more than 5 years out), and you found more relevant up-to-date data. Regarding the articles meeting eligibility, but not included in this review, your team did well. For example, I agree that the falls articles you excluded, while relatively favorable to tai chi, were all too old (i.e. 2016–2018). It was nice to see a follow up on conditions that were evaluated in the past review, as well as adding new topic areas. However, I feel that you downgraded level of evidence for some items. For example, most federal agencies (National Council on Aging, CDC and STEADI) would advocate that there is HIGH efficacy for tai chi for falls/balance, osteoarthritis, and Parkinson’s. | We would like to clarify that we did not perform evidence rating and reported the certainty of evidence ratings directly from the respective reviews. Thus, we understand that the reviewer may disagree with how the authors of the original review labeled the certainty of evidence, but we are not able to change that.
23 | 4 | RE: Literature Review Process for Tai Chi and Health Promotion First, since you are referencing the article as Tai chi/Qigong for Health and Well-being, I found it curious there was no specific literature review (“Search”) related to:; - “Tai chi and/or Qigong and Health Promotion”; - “Tai chi and/or Qigong and Well-Being”; - “Tai chi and/or Qigong and Health Benefits”; I’ve done these literature reviews several times as I teach a primary prevention course at the University of Wisconsin Doctor of Physical Therapy program. | Development of the search strategy was done with input from a librarian with expertise in systematic reviews. We understand that developing such search strategies is not a task which when performed by similarly skilled individuals will always result in exactly the same output, and thus acknowledge that there are other search strategies possible. But we cannot go back and change the search strategy now, but if there were some systematic reviews on those topics that we missed we would consider adding this information to the limitations.
24 | 4 | Given that the VA utilizes the whole health approach, I would think a search with the above mesh terms may yield a more holistic view of the benefits of these mind-body interventions. Given that preventative care of noncommunicable diseases is a key part of healthcare, these scoping reviews of meta-analysis below may be highly relevant to your review process. All promote the view that “Tai Chi exercise is a feasible and effective method for preventing diseases and promoting health.” | We have reviewed each one and found that our search had identified these 6 references, but all were excluded based on inclusion/exclusion stated in Methods.
25 | 4 | As a mind-body exercise; Tai Chi fights back on the diseases of aging and the top causes of morbidity/mortality. Below are my TOP articles that I think you missed for this review.; 1. Easwaran K, Gopalasingam Y, Green D D, Lach V, Melnyk JA, Wan C, Bartlett DJ. Effectiveness of Tai Chi for health promotion for adults with health conditions: a scoping review of Meta-analyses. Disabil Rehabil. 2021 Oct;43(21):2978–2989. doi: 10.1080/09638288.2020.1725916. Epub 2020 Feb 18. PMID: 3207013732070137; ABSTRACT; Purpose: To complete a scoping review of meta-analyses summarizing evidence of the effectiveness of Tai Chi for adults with health conditions.; Materials and methods: Meta-analyses were retrieved from Medline, Embase, AMED, CINAHL, SPORTDiscus, PsychINFO, Web of Science, PubMed Health and the Cochrane Library from database inception to early September 2018. Multistage deduplication and screening processes identified full-length, unique, peer-reviewed meta-analyses. Two people independently appraised 42 meta-analyses based on the GRADE system and organized results into 3 appendices subsequently collated into heterogeneous, statistically significant, and statistically insignificant tables.; Results: “High” and “moderate” quality evidence indicates that Tai Chi can significantly benefit adults with health conditions including cancers, chronic obstructive pulmonary disease, coronary heart disease, depression, heart failure, hypertension, low back pain, osteoarthritis, osteoporosis, Parkinson’s Disease and stroke. Outcomes included significant improvements in activities of daily living, balance, exercise capacity, gait, mastery, mental health, mobility, motor function, participation in daily life, physical function, quality of life, range of motion, and strength; with reductions in blood pressure, body mass index, depression, disability, dyspnea, falls, fatigue, pain, stiffness, and waist circumference.; Conclusions: Healthcare providers now have information to advise clients with health conditions on the effectiveness of Tai Chi for overall health promotion. IMPLICATIONS FOR REHABILITATION: Tai Chi is a form of safe, enjoyable, light-to-moderate aerobic physical activity for adults that is inexpensive to implement in diverse community settings. Adults with health conditions require physical activity for prevention of secondary impairments and over-all health promotion. This scoping review of meta-analyses elucidates “high” and “moderate” quality evidence of the effectiveness of Tai Chi in improving important outcomes for people with numerous health conditions. This information can be useful for healthcare providers who wish to recommend effective community-based physical activity to clients they are serving.; Keywords: PubMed; Tai Ji; adults; health promotion; meta-analysis. | Excluded at title screening because it is a scoping review
26 | 4 | 2. Yang FC, Desai AB, Esfahani P, Sokolovskaya TV, Bartlett DJ. Effectiveness of Tai Chi for Health Promotion of Older Adults: A Scoping Review of Meta-Analyses . Am J Lifestyle Med. 2021 Mar 24;16(6):700–716.36389043 | Excluded at abstract because it is a scoping review
27 | 4 | 3. Huang J, Wang D, Wang J. Clinical Evidence of Tai Chi Exercise Prescriptions: A Systematic Review. Evid Based Complement Alternat Med. 2021 Mar 10;2021:5558805.33777155 | Excluded at abstract (not about effectiveness)
28 | 4 | 4. Yang GY, Sabag A, Hao WL, Zhang LN, Jia MX, Dai N, Zhang H, Ayati Z, Cheng YJ, Zhang CH, Zhang XW, Bu FL, Wen M, Zhou X, Liu JP, Wayne PM, Ee C, Chang D, Kiat H, Hunter J, Bensoussan A. Tai Chi for health and well-being: A bibliometric analysis of published clinical studies between 2010 and 2020. Complement Ther Med. 2021 Aug;60:102748. doi: 10.1016/j.ctim.2021.102748. Epub 2021 Jun 10.PMID: 34118389 Free article. Review.34118389 | Excluded at full text (did not grade evidence)
29 | 4 | 5. Lee LY, Chu EC. Tai Chi as a Body-Mind Exercise for Promotion of Healthy Aging in Nursing Home Residents: Appropriateness, Feasibility, and Effectiveness. Clin Interv Aging. 2023 Nov 23;18:1949–1959. doi: 10.2147/CIA.S430968. eCollection 2023.PMID: 38020454 Free PMC article. Review.38020454 | Excluded at full text (did not grade evidence)
30 | 4 | 6. Taylor J, Walsh S, Kwok W, Pinheiro MB, de Oliveira JS, Hassett L, Bauman A, Bull F, Tiedemann A, Sherrington C. A scoping review of physical activity interventions for older adults. Int J Behav Nutr Phys Act. 2021 Jun 30;18(1):82. doi: 10.1186/s12966-021-01140-9.PMID: 34193157 Free PMC article.34193157 | Excluded at full text because it is a scoping review
31 | 5 | Yes - Additional systematic reviews | We have reviewed each of the suggested publications.; 1 review cognition in neurological disorders is already included on the map, perhaps the reviewers had inadvertently missed it. One review that was published after our search date is a more informative review with more primary studies, and replaced the existing review about chronic low back pain that is already on the map.; Below are the reasons for exclusion for the others:
32 | 5 | Falls; 141. Zou L, Han J, Li C, Effects of Tai Chi on Lower Limb Proprioception in Adults Aged Over 55: A Systematic Review and Meta-Analysis. Arch Phys Med Rehabil. Jun 2019;100(6):1102–1113. doi:10.1016/j.apmr.2018.07.425 30125554; 142. Wehner C, Blank C, Arvandi M, Wehner C, Schobersberger W. Effect of Tai Chi on muscle strength, physical endurance, postural balance and flexibility: a systematic review and meta-analysis. BMJ Open Sport Exerc Med. 2021;7(1):e000817. doi:10.1136/bmjsem-2020-000817 | Excluded at full text screening (Did not grade evidence)
33 | 5 | 142. Wehner C, Blank C, Arvandi M, Wehner C, Schobersberger W. Effect of Tai Chi on muscle strength, physical endurance, postural balance and flexibility: a systematic review and meta-analysis. BMJ Open Sport Exerc Med. 2021;7(1):e000817. doi:10.1136/bmjsem-2020-000817 | Excluded at full text screening (Did not grade evidence)
34 | 5 | Cognition; 146. Wayne PM, Walsh JN, Taylor-Piliae RE, Effect of tai chi on cognitive performance in older adults: systematic review and meta-analysis. J Am Geriatr Soc. Jan 2014;62(1):25–39. doi:10.1111/jgs.12611 24383523 | Excluded at full text screening (Did not grade evidence)
35 | 5 | 154. Liu J, Shi H, T L. Qigong exercise and cognitive function in brain imaging studies: A systematic review of randomized controlled trials in healthy and cognitively impaired populations. Brain Brahvior and Immunity Integrative. 2023;3(100016)doi:doi.org/10.1016/j.bbii.2023.100016 | Excluded at full text screening (Did not grade evidence)
36 | 5 | 155. Chen ML, Wotiz SB, Banks SM, Connors SA, Shi Y. Dose-Response Association of Tai Chi and Cognition among Community-Dwelling Older Adults: A Systematic Review and Meta-Analysis. Int J Environ Res Public Health. Mar 19 2021;18(6)doi:10.3390/ijerph18063179 | Excluded at full text screening (Did not grade evidence)
37 | 5 | 156. Lim KH, Pysklywec A, Plante M, Demers L. The effectiveness of Tai Chi for short-term cognitive function improvement in the early stages of dementia in the elderly: a systematic literature review. Clin Interv Aging. 2019;14:827–839. doi:10.2147/CIA.S202055 31190769 | Excluded at full text screening (Did not grade evidence)
38 | 5 | 157. Wang Y, Zhang Q, Li F, Li Q, Jin Y. Effects of tai chi and Qigong on cognition in neurological disorders: A systematic review and meta-analysis. Geriatr Nurs. Jul-Aug 2022;46:166–177. doi:10.1016/j.gerinurse.2022.05.014 35704955 | INCLUDED IN MAP Parkinson’s disease—cognition / mild cognitive impairment—cognition
39 | 5 | 158. Wei L, Chai Q, Chen J, The impact of Tai Chi on cognitive rehabilitation of elder adults with mild cognitive impairment: a systematic review and meta-analysis. Disabil Rehabil. Jun 2022;44(11):2197–2206. doi:10.1080/09638288.2020.1830311 33043709 | Excluded at full text screening (Did not grade evidence)
40 | 5 | 163. Cai H, Zhang K, Wang M, Li X, Ran F, Han Y. Effects of mind-body exercise on cognitive performance in middle-aged and older adults with mild cognitive impairment: A meta-analysis study. Medicine (Baltimore). Aug 25 2023;102(34):e34905. doi:10.1097/MD.0000000000034905 Mental health37653776 | Excluded at full text screening (Did not grade evidence)
41 | 5 | Mental health; 164. Liu F, Cui J, Liu X, Chen KW, Chen X, Li R. The effect of tai chi and Qigong exercise on depression and anxiety of individuals with substance use disorders: a systematic review and meta-analysis. BMC Complement Med Ther. May 29 2020;20(1):161. doi:10.1186/s12906-020-02967-8 32471415 | Excluded at full text screening (Did not grade evidence)
42 | 5 | 165. Liu X, Clark J, Siskind D, A systematic review and meta-analysis of the effects of Qigong and Tai Chi for depressive symptoms. Complement Ther Med. Aug 2015;23(4):516–34. doi:10.1016/j.ctim.2015.05.001 26275645 | Excluded at full text screening (Did not grade evidence)
43 | 5 | 166. Choo YT, Jiang Y, Hong J, Wang W. Effectiveness of Tai Chi on quality of life, depressive symptoms and physical function among community-dwelling older adults with chronic disease: A systematic review and meta-analysis. Int J Nurs Stud. Nov 2020;111:103737. doi:10.1016/j.ijnurstu.2020.103737 32891966 | Excluded at full text screening (Did not grade evidence)
44 | 5 | 167. Sani NA, Yusoff SSM, Norhayati MN, Zainudin AM. Tai Chi Exercise for Mental and Physical Well-Being in Patients with Depressive Symptoms: A Systematic Review and Meta-Analysis. Int J Environ Res Public Health. Feb 5 2023;20(4)doi:10.3390/ijerph20042828 | Excluded at full text screening (Did not grade evidence)
45 | 5 | 168. Taylor-Piliae RE, Finley BA. Tai Chi exercise for psychological well-being among adults with cardiovascular disease: A systematic review and meta-analysis. Eur J Cardiovasc Nurs. Oct 2020;19(7):580–591. doi:10.1177/1474515120926068 32515204 | Excluded at full text screening (Did not grade evidence)
46 | 5 | 169. Niles BL, Reid KF, Whitworth JW, Tai Chi and Qigong for trauma exposed populations: A systematic review. Ment Health Phys Act. Mar 2022;22doi:10.1016/j.mhpa.2022.100449 | Excluded at full text screening (Did not grade evidence)
47 | 5 | 172. Zhang Z, Chang X, Zhang W, Yang S, Zhao G. The Effect of Meditation-Based Mind-Body Interventions on Symptoms and Executive Function in People With ADHD: A Meta-Analysis of Randomized Controlled Trials. J Atten Disord. Apr 2023;27(6):583–597. doi:10.1177/10870547231154897 36803119 | Excluded at abstract screening (Outcomes for interventions of interest not reported separately)
48 | 5 | 176. Yin J, Yue C, Song Z, Sun X, Wen X. The comparative effects of Tai chi versus non-mindful exercise on measures of anxiety, depression and general mental health: A systematic review and meta-analysis. J Affect Disord. Sep 15 2023;337:202–214. doi:10.1016/j.jad.2023.05.037 37244543 | Excluded at full text screening (Did not grade evidence)
49 | 5 | 179. Zou L, Yeung A, Li C, Effects of Meditative Movements on Major Depressive Disorder: A Systematic Review and Meta-Analysis of Randomized Controlled Trials. J Clin Med. Aug 1 2018;7(8)doi:10.3390/jcm7080195 | Excluded at abstract screening (Outcomes for interventions of interest not reported separately)
50 | 5 | Immune; 189. Morgan N, Irwin MR, Chung M, Wang C. The effects of mind-body therapies on the immune system: meta-analysis. PLoS One. 2014;9(7):e100903. doi:10.1371/journal.pone.0100903 24988414 | Excluded at full text screening (Did not grade evidence)
51 | 5 | Sleep; 197. Ko LH, Hsieh YJ, Wang MY, Hou WH, Tsai PS. Effects of health qigong on sleep quality: A systematic review and meta-analysis of randomized controlled trials. Complement Ther Med. Dec 2022;71:102876. doi:10.1016/j.ctim.2022.102876 35998756 | Excluded at full text screening (Did not grade evidence)
52 | 5 | 198. Li H, Chen J, Xu G, The Effect of Tai Chi for Improving Sleep Quality: A Systematic Review and Meta-analysis. J Affect Disord. Sep 1 2020;274:1102–1112. doi:10.1016/j.jad.2020.05.076 32663938 | Excluded at full text screening (Did not grade evidence)
53 | 5 | 199. Raman G, Zhang Y, Minichiello VJ, D'Ambrosio CM, Wang C. Tai Chi Improves Sleep Quality in Healthy Adults and Patients with Chronic Conditions: A Systematic Review and Meta-analysis. J Sleep Disord Ther. Oct 2013;2(6)doi:10.4172/2167-0277.1000141 | Published before current review’s search dates, reviewed and excluded (Did not grade evidence)
54 | 5 | 200. Si Y, Wang C, Yin H, Tai Chi Chuan for Subjective Sleep Quality: A Systematic Review and Meta-Analysis of Randomized Controlled Trials. Evid Based Complement Alternat Med. 2020;2020:4710527. doi:10.1155/2020/4710527 32849900 | Excluded at full text screening (Did not grade evidence)
55 | 5 | Hypertension; 214. Yin Y, Yu Z, Wang J, Sun J. Effects of the different Tai Chi exercise cycles on patients with essential hypertension: A systematic review and meta-analysis. Front Cardiovasc Med. 2023;10:1016629. doi:10.3389/fcvm.2023.1016629 36937925 | Excluded at full text screening (Did not grade evidence)
56 | 5 | Cardiovascular risk; 219. Liu T, Chan AW, Liu YH, Taylor-Piliae RE. Effects of Tai Chi-based cardiac rehabilitation on aerobic endurance, psychosocial well-being, and cardiovascular risk reduction among patients with coronary heart disease: A systematic review and meta-analysis. Eur J Cardiovasc Nurs. Apr 2018;17(4):368–383. doi:10.1177/1474515117749592 29256626 | Excluded at full text screening (Did not grade evidence)
57 | 5 | Heart Failure; 220. Bao Q, Lei S, Guo S, Effect of Traditional Chinese Exercises on Patients with Chronic Heart Failure (TCE-HF): A Systematic Review and Meta-Analysis. J Clin Med. Mar 9 2023;12(6)doi:10.3390/jcm12062150 | Excluded at full text screening (Did not grade evidence)
58 | 5 | COPD; 227. Gendron LM, Nyberg A, Saey D, Maltais F, Lacasse Y. Active mind-body movement therapies as an adjunct to or in comparison with pulmonary rehabilitation for people with chronic obstructive pulmonary disease. Cochrane Database Syst Rev. Oct 10 2018;10(10):CD012290.30306545 | Excluded at abstract screening (Outcomes for interventions of interest not reported separately)
59 | 5 | Pain; 233. Kong LJ, Lauche R, Klose P, Tai Chi for Chronic Pain Conditions: A Systematic Review and Meta-analysis of Randomized Controlled Trials. Sci Rep. Apr 29 2016;6:25325. doi:10.1038/srep25325 27125299 | Excluded at full text screening (Did not grade evidence)
60 | 5 | 235. Zou L, Xiao T, Cao C, Tai Chi for Chronic Illness Management: Synthesizing Current Evidence from Meta-Analyses of Randomized Controlled Trials. Am J Med. Feb 2021;134(2):194–205 e12. doi:10.1016/j.amjmed.2020.08.015 32946848 | Excluded at abstract screening (Not a systematic review)
61 | 5 | 236. Qin J, Zhang Y, Wu L, Effect of Tai Chi alone or as additional therapy on low back pain: Systematic review and meta-analysis of randomized controlled trials. Medicine (Baltimore). Sep 2019;98(37):e17099. doi:10.1097/MD.0000000000017099 31517838 | Excluded at full text screening (Did not grade evidence)
62 | 5 | 238. Girard J, Girard A. The effects of qigong on neck pain: A systematic review. Complement Ther Clin Pract. Feb 2019;34:23–29. doi:10.1016/j.ctcp.2018.10.013 30712732 | Excluded at full text screening (Did not grade evidence)
63 | 5 | 239. Liu Z, Hu H, Wen X, Baduanjin improves neck pain and functional movement in middle-aged and elderly people: A systematic review and meta-analysis of randomized controlled trials. Front Med (Lausanne). 2022;9:920102. doi:10.3389/fmed.2022.920102 36703891 | Excluded at full text screening (Did not grade evidence)
64 | 5 | 245. Ye J, Cai S, Zhong W, Cai S, Zheng Q. Effects of tai chi for patients with knee osteoarthritis: a systematic review. J Phys Ther Sci. Jul 2014;26(7):1133–7. doi:10.1589/jpts.26.1133 25140112 | Excluded at full text screening (Did not grade evidence)
65 | 5 | 246. Chang WD, Chen S, Lee CL, Lin HY, Lai PT. The Effects of Tai Chi Chuan on Improving Mind-Body Health for Knee Osteoarthritis Patients: A Systematic Review and Meta-Analysis. Evid Based Complement Alternat Med. 2016;2016:1813979. doi:10.1155/2016/1813979 27635148 | Excluded at full text screening (Did not grade evidence)
66 | 5 | 248. You Y, Liu J, Tang M, Wang D, Ma X. Effects of Tai Chi exercise on improving walking function and posture control in elderly patients with knee osteoarthritis: A systematic review and meta-analysis. Medicine (Baltimore). Apr 23 2021;100(16):e25655. doi:10.1097/MD.0000000000025655 33879749 | Excluded at full text screening (Did not grade evidence)
67 | 5 | 249. Kelley GA, Kelley KS, Callahan LF. Clinical relevance of Tai Chi on pain and physical function in adults with knee osteoarthritis: An ancillary meta-analysis of randomized controlled trials. Sci Prog. Apr-Jun 2022;105(2):368504221088375. doi:10.1177/00368504221088375 35379041 | Excluded at full text screening (Did not grade evidence)
68 | 5 | 255. Wu H, Wang Q, Wen G, Wu J, Wang Y. The effects of Tai Chi on physical function and safety in patients with rheumatoid arthritis: A systematic review and meta-analysis. Front Physiol. 2023;14:1079841. doi:10.3389/fphys.2023.1079841 36776976 | Excluded at full text screening (Did not grade evidence)
69 | 5 | 256. Kang H, Yang M, Li M, Xi R, Sun Q, Lin Q. Effects of different parameters of Tai Chi on the intervention of chronic low back pain: A meta-analysis. PLoS One. 2024;19(7):e0306518. doi:10.1371/journal.pone.0306518 38980862 | Published after our search date, reviewed for eligibility and replaced current mapped review for Chronic Low Back Pain
70 | 5 | 257. Wang XQ, Xiong HY, Du SH, Yang QH, Hu L. The effect and mechanism of traditional Chinese exercise for chronic low back pain in middle-aged and elderly patients: A systematic review. Front Aging Neurosci. 2022;14:935925. doi:10.3389/fnagi.2022.935925 36299610 | Excluded at full text screening (Did not grade evidence)
71 | 5 | 258. Kong L, Ren J, Fang S, He T, Zhou X, Fang M. Traditional Chinese Exercises on Pain and Disability in Middle-Aged and Elderly Patients With Neck Pain: A Systematic Review and Meta-Analysis of Randomized Controlled Trials. Front Aging Neurosci. 2022;14:912945. doi:10.3389/fnagi.2022.912945 35754953 | Excluded at full text screening (Did not grade evidence)
72 | 5 | Cancer; 263. Cheung DST, Takemura N, Smith R, Effect of qigong for sleep disturbance-related symptom clusters in cancer: a systematic review and meta-analysis. Sleep Med. Sep 2021;85:108–122. doi:10.1016/j.sleep.2021.06.036 34303913 | Excluded at full text screening (Did not grade evidence)
73 | 5 | 274. Oh B, Bae K, Lamoury G, The Effects of Tai Chi and Qigong on Immune Responses: A Systematic Review and Meta-Analysis. Medicines (Basel). Jun 30 2020;7(7)doi:10.3390/medicines7070039 | Excluded at full text screening (Did not grade evidence)
74 | 5 | 277. Yang L, Winters-Stone K, Rana B, Tai Chi for cancer survivors: A systematic review toward consensus-based guidelines. Cancer Medicine. 2021;10(21):7447–7456. doi:10.1002/cam4.4273 34533284 | Excluded at full text screening (Did not grade evidence)
75 | 5 | 278. Meng T, Hu S-f, Cheng Y-q, Qigong for women with breast cancer: An updated systematic review and meta-analysis. Complementary Therapies in Medicine. 2021/08/01/ 2021;60:102743. doi:10.1016/j.ctim.2021.102743 34058368 | Excluded at full text screening (Did not grade evidence)
76 | 5 | 280. Wayne PM, Lee MS, Novakowski J, Tai Chi and Qigong for cancer-related symptoms and quality of life: a systematic review and meta-analysis. Journal of Cancer Survivorship. 2018/04/01 2018;12(2):256–267. doi:10.1007/s11764-017-0665-5 29222705 | Excluded at full text screening (Did not grade evidence)
77 | 5 | 281. Sun F, Li L, Wen X, Xue Y, Yin J. The effect of Tai Chi/Qigong on depression and anxiety symptoms in adults with Cancer: A systematic review and meta-regression. Complementary Therapies in Clinical Practice. 2024/08/01/ 2024;56:101850. doi:10.1016/j.ctcp.2024.101850 38626582 | Published after our search date, reviewed for eligibility and added to map for Anxiety
78 | 7 | Yes - There were numerous Tai Chi and Qigong reviews that were not cited. An example is “Chang PS, Knobf T, Oh B, et al. Physical, and psychological health outcomes of Qigong exercise in older adults: a systematic review and meta-analysis. Am J Chin Med. 2019;47(2):301–322.” | We did identify this in our search but the review was excluded because the authors did not provide certainty of evidence ratings.
Additional suggestions:
Comment # | Reviewer # | Comment | Author Response
79 | 1 | 1. As noted above, the conclusions for Falls seems to under value the quality and quantity of research. Multiple large scale and rigorous trials (e.g. Fuzhong Li et al) add significantly to evidence base for Tai Chi and falls. Some new studies on cognitive function by this group also noteworthy. If these are not yet formally integrated into SRs that meet your inclusion criteria, might be worth mentioning in discussion that new data might change classification. There also are some newer large scale trials on insomnia worth mentioning. | Please see our response to comment 16 above.
80 | 1 | 2. While I see some value is listing country of authors of SRs in synthesis table, what is more important is country in which (majority of) trials were conducted. Case in point is Osteoporosis. The vast majority of these studies were conducted in China. Because Asian women (focus of most studies) have different bone turnover metabolisms compared with Caucasian, Hispanic, and African Americans, we do not know how translatable this research is--not to mention cultural difference is perceptions of tai chi). This should be at least addressed in discussion. | We have added this in discussion.
81 | 1 | 3. Some mention on methods for reporting AEs should be elaborated on in discussion. Wayne et al 2014 and other have shown that very very few RCTs including formal protocols for systematically monitoring AEs in all intervention groups. So safety data needs to be interpreted cautiously. | We have added this in discussion.
82 | 1 | 4. I do not support a separate category of Baduanjin. While it has received a bit more attention that other forms of qigong, it is not particularly more or less important than any other ‘style’. Of note, like tai chi, there is significant pluralism in what is taught as Badunajin--different movements, names, etc. So I suggest simply folding it into ‘Qigong” category. | Thank you for your comment. We have combined Baduanjin and qigong into one category on the map.
83 | 1 | 5. I have some concerns with definition and references for ‘Qi’ on page 4. I think there are better/less confusing definitions than “the body’s natural airflow’. Qi is a complex topic and whole books about definitions have been written (see Brief hHstory of Qi--Huang and Rose). While the Chinese character ‘breath’ is sometimes misconstrued with Qi, natural airflow is definitely misleading. How does air flow through meridians--as noted in following phrase in this section? Some suggestions for wording can be found in Harvard Medical School Guide to Tai CHi. | Thank you for your comment. We have revised the introduction.
84 | 1 | 6. Pg 7--not sure why ‘massage therpay’ is mentioned? | We have made the change.
85 | 1 | 7. In table 1, groupings potentially a bit confusing. While there is a section on Parkinson’s, no mention is made on strong data for fall prevention. For Tai Chi and Falls in general, no distinction is made on populations--- healthy ambulatory older adults, higher risk fallers, PD, Stroke, MCI, those living in assisted living facilities. Benefits vary significantly depending on subgroups. Insomnia also good example of complexity. Insomnia shown helpful in cancer and with those with sleep disorders. How do you describe/convery these nuanced differences | Thank you for this comment. This problem is common to all “review of reviews” products such as this one, where we must accept how the authors of the included systematic review found, organized, and synthesized the studies included in their review. The only way we can include information about subgroups is if the original authors of the included review did those subgroup analyses. In the absence of these subgroup analyses, our only recourse is to perform a new systematic review ourselves of the original studies, with subgroup analyzes of our choosing. Perhaps the reviewer would consider submitting a proposal to the Coordinating Center to suggest this as a topic for a future evidence review.
86 | 1 | 8. In characteristics of reviews, for some there is mention of how many of trials did one style (e.g. Yang 24) vs another (e.g. Chen). While it’s ok to acknowledge/report this, not clear how readers are supposed to use/interpret this. Suggest adding is Discussion, since few well designed back-to-back comparisons of relative effectiveness of styles/forms/etc, caution should be applied in interpreting statements of superiority of one form vs another, and future research should address this gap. | We have added details in discussion.
87 | 2 | There were a number of grammatical errors and typos that I am sure will be corrected in the final version. There are several areas where there are typos that need to be addressed. Also there needs to be a decision about what is capitalized. The document has “tai chi”, “Tai chi” and “Tai Chi”. Otherwise very good job on this review and the information will be valuable for the field. | Thank you for your comment. We have made revisions throughout the report.
88 | 3 | There are several areas where there are typos that need to be addressed. One place has an artifact of Medical Massage Therapy. Also there needs to be a decision about what is capitalized. The document has “tai chi”, “Tai chi” and “Tai Chi”. Otherwise very good job on this review and the information will be valuable for the field. | We have made changes throughout report.
89 | 4 | RE: Search engines used for your paper; I am also curious about the databases you selected, specifically no PubMed: National Library of Medicine. I respect that this may be much too late in your writing process, but I respectfully think you might have missed some articles worth exploring.; Out of curiosity I did my own search using similar methodology: “Tai chi and ___”, systematic reviews, last 5 years) in PubMed: National Library of Medicine. I specifically used many of your key topics. Below you will see some of the articles I think you may have missed or excluded. | Thank you for your comment. Ovid/Medline database includes results from PubMed. We would like to refer the reviewer to a previous response about any reviews that we may have missed.
90 | 4 | Pub Med: “Tai Chi and Back Pain” (11 systematic reviews in last 5 years); - Li Y, Yan L, Hou L, Zhang X, Exercise intervention for patients with chronic low back pain: a systematic review and network meta-analysis. Front Public Health. 2023 Nov 17;11:1155225. doi: 10.3389/fpubh.2023.1155225.38035307; Conclusion: Compared with conventional rehabilitation and no intervention provided, tai chi, yoga, Pilates exercise, sling exercise, motor control exercise, and core or stabilization exercises significantly improved chronic low back pain (CLBP) in patients. | Excluded at full text screening (Did not grade evidence)
91 | 4 | Pub Med: “Tai Chi and Cancer-related symptoms” (9 systematic reviews in last 5 years); - Bower JE, Lacchetti C, Alici Y, Barton DL, Management of Fatigue in Adult Survivors of Cancer: ASCO-Society for Integrative Oncology Guideline Update. J Clin Oncol. 2024 Jul 10;42(20):2456–2487.38754041; Recommendations: Clinicians should recommend exercise, CBT, mindfulness-based programs, and tai chi or qigong to reduce the severity of fatigue during cancer treatment. | Published after our search date, reviewed for eligibility and added to map for Cancer-related Fatigue.
92 | 4 | - Casuso-Holgado MJ, Heredia-Rizo AM, Gonzalez-Garcia P, Muñoz-Fernández MJ, Mind-body practices for cancer-related symptoms management: an overview of systematic reviews including one hundred twenty-nine meta-analyses. Support Care Cancer. 2022 Dec;30(12):10335–10357. doi: 10.1007/s00520-022-07426-3.36322248; Conclusions: Qigong, tai chi, and yoga could be effective approaches to relief cancer-related symptoms in adults with different cancer diagnoses. (N=38 articles, 134 distinct primary studies and 129 separate meta-analyses were included). | Published after search date, reviewed and included on map for Cancer – Anxiety
93 | 4 | - RCT: Takemura N, Cheung DST, Fong DYT, Hui D, Tai Chi and Aerobic Exercise on Cancer-Related Dyspnea in Advanced Lung Cancer Patients: A Randomized Clinical Trial. J Pain Symptom Manage. 2024 Aug;68(2):171–179.38729532; Conclusion: Both TC and AE alleviate dyspnea severity in patients with advanced lung cancer, and continuous exercise can yield substantial improvements. Due to its multi-component nature, Tai Chi has a greater effect on dyspnea. | Excluded at abstract screening (Not a systematic review)
94 | 4 | PubMed: “Tai Chi and Cognition” (69 systematic reviews in the last 5 years); - Li F, Wang L, Qin Y, Liu G. Combined Tai Chi and cognitive interventions for older adults with or without cognitive impairment: A meta-analysis and systematic review. Complement Ther Med. 2022 Aug;67:102833. doi: 10.1016/j.ctim.2022.102833.35439549; Results: A total of 1524 records were generated and nine studies were included. The pooled results showed that combined TC and cognitive interventions showed significantly large gains on memory [standardised mean difference (SMD) = 0.87, 95% confidence interval (CI): (0.01, 1.74), P 0.05], moderate gains on cognition [SMD = 0.74, 95% CI:(0.19, 1.29), P 0.05], and small size effects on balance. No statistically significant difference was found in executive function, depression, risk of falls, or well-being.; Conclusion: Combined TC and cognitive interventions have positive effects on improving cognition and balance in older adults, but their superiority over the single intervention, as well as their additional effects on the physical and psychological function, are required further investigation. | Excluded at full text screening (Did not grade evidence)
95 | 4 | - Park M, Song R, Ju K, Shin JC, Effects of Tai Chi and Qigong on cognitive and physical functions in older adults: systematic review, meta-analysis, and meta-regression of randomized clinical trials. BMC Geriatr. 2023 Jun 6;23(1):352. doi: 10.1186/s12877-023-04070-2.37280512; Conclusion: This meta-regression of 17 randomized studies strongly suggests that TCQ has beneficial effects on physical and cognitive functions in older adults. The effect of TCQ on cognitive function remained significant after taking into account the significant effects of physical function as a moderator. The findings imply the potential health benefits of TCQ by promoting cognitive function in older adults directly and indirectly through enhancing physical function. | Excluded at full text screening (Did not grade evidence)
96 | 4 | - Wang Y, Zhang Q, Li F, Li Q, Jin Y. Effects of tai chi and Qigong on cognition in neurological disorders: A systematic review and meta-analysis. Geriatr Nurs. 2022 Jul-Aug;46:166–177. doi: 10.1016/j.gerinurse.2022.05.014.35704955; Conclusions: Tai chi and Qigong were effective interventions to improve cognition in patients with Parkinson’s disease, stroke, mild cognitive impairment, dementia, and traumatic brain injury; however, no RCTs were performed for other neurological disorders. (N=40 RCTs with 2,754 subjects) | Already included in map
97 | 4 | - Tsai FJ, Shen SW. Concepts of dementia prevention in the health promotion among older adults: A narrative review. Medicine (Baltimore). 2022 Dec 16;101(50):e32172. doi: 10.1097/MD.0000000000032172.PMID: 36550862 Free PMC article. Review.36550862 | Excluded at title screening
98 | 4 | PubMed: Tai Chi and Depression; - Zhu F, Wang Y, Yin S, Liu J, Zhong Y, Li L. The effect of Tai Chi on elderly depression: a systematic review and meta-analysis of randomized controlled trials. Front Psychol. 2024 Nov 29;15:1489384. doi: 10.3389/fpsyg.2024.1489384. eCollection 2024.PMID: 39679159 Free PMC article.39679159 | Published after search date, reviewed and excluded at full text screening (Did not grade evidence)
99 | 4 | PubMed: ‘Tai Chi and Falls” (29 systematic reviews in last 5 years); - Chen W, Li M, Li H, Lin Y, Feng Z. Tai Chi for fall prevention and balance improvement in older adults: a systematic review and meta-analysis of randomized controlled trials. Front Public Health. 2023 Sep 1;11:1236050. doi: 10.3389/fpubh.2023.1236050.37736087; Results: Totally 24 RCTs were included for meta-analysis, and the results showed that Tai Chi can effectively reduce the risk of falls in older adults (RR: 0.76, 95% CI: 0.71 to 0.82) and decrease the number of falls (MD [95% CI]: −0.26 [−0.39, −0.13]). Tai Chi can also improve the balance ability of older adults, such as the timed up and go test (MD [95% CI]: −0.69 [−1.09, −0.29]) and the functional reach test (MD [95% CI]: 2.69 [1.14, 4.24]), as well as other balance tests such as single-leg balance test, Berg balance scale, and gait speed (p < 0.05). Subgroup analysis showed that Tai Chi is effective for both healthy older adults and those at high risk of falls (p < 0.001), and its effectiveness increases with the duration and frequency of exercise. In addition, the effect of Yang-style Tai Chi is better than that of Sun-style Tai Chi.; Conclusion: Tai Chi is an effective exercise for preventing falls and improving balance ability in older adults, whether they are healthy or at high risk of falling. The effectiveness of Tai Chi increases with exercise time and frequency. Yang-style Tai Chi is more effective than Sun-style Tai Chi. | Excluded at full text screening (Did not grade evidence)
100 | 4 | - Sherrington C, Fairhall N, Kwok W, Wallbank G, Tiedemann A, Michaleff ZA, Ng CACM, Bauman A. Evidence on physical activity and falls prevention for people aged 65+ years: systematic review to inform the WHO guidelines on physical activity and sedentary behaviour. Int J Behav Nutr Phys Act. 2020 Nov 26;17(1):144. doi: 10.1186/s12966-020-01041-3.33239019; Results: This review included 116 studies, involving 25,160 participants; nine new studies since the 2019 Cochrane Review. Exercise reduces the rate of falls by 23% (pooled rate ratio (RaR) 0.77, 95% confidence interval (CI) 0.71 to 0.83, 64 studies, high certainty evidence). Subgroup analysis showed variation in effects of different types of exercise (p < 0.01). Rate of falls compared with control is reduced by 24% from balance and functional exercises (RaR 0.76, 95% CI 0.70 to 0.82, 39 studies, high certainty evidence), 28% from programs involving multiple types of exercise (commonly balance and functional exercises plus resistance exercises, RaR 0.72, 95% CI 0.56 to 0.93, 15 studies, moderate certainty evidence) and 23% from Tai Chi (RaR 0.77, 95% CI 0.61 to 0.97, 9 studies, moderate certainty evidence). The effects of programs that primarily involve resistance training, dance or walking remain uncertain. Interventions with a total weekly dose of 3+ hours that included balance and functional exercises were particularly effective with a 42% reduction in rate of falls compared to control (Incidence Rate Ratio (IRR) 0.58, 95% CI 0.45 to 0.76). Subgroup analyses showed no evidence of a difference in the effect on falls on the basis of participant age over 75 years, risk of falls as a trial inclusion criterion, individual versus group exercise, or whether a health professional delivered the intervention.; Conclusions: Given the strength of this evidence, effective exercise programs should now be implemented at scale. | Excluded at full text in favor of a more informative review (falls prevention)
101 | 4 | Falls prevention interventions for community-dwelling older adults: systematic review and meta-analysis of benefits, harms, and patient values and preferences.; Pillay J, Gaudet LA, Saba S, Vandermeer B, Ashiq AR, Wingert A, Hartling L.Syst Rev. 2024 Nov 26;13(1):289. doi: 10.1186/s13643-024-02681-3.PMID: 3959315939593159 | Published after our search date, reviewed for eligibility and added to map for falls prevention.
102 | 4 | PubMed; “Tai Chi and Falls, Parkinson’s (6 systematic reviews in last 5 years); - Aras B, Seyyar GK, Fidan O, Colak E. The effect of Tai Chi on functional mobility, balance and falls in Parkinson's disease: A systematic review and meta-analysis of systematic reviews. Explore (NY). 2022 Jul-Aug;18(4):402–410. doi: 10.1016/j.explore.2021.34952799 (N=601 studies up to Oct 2021, N=11 in review).; Results: According to our meta-analysis; there was a significant effect of Tai Chi on balance (SMD, −0.777 95% CI −0.921 to −0.633; p = 0.000), functional mobility (SMD, −0.719 95% CI −0.944 to −0.494; p = 0.000), and falls (SMD, −0.456 95% CI −0.668 to −0.245; p = 0.000) in PD.; Conclusion: Our systematic review and meta-analysis found significant effects of Tai Chi on functional mobility, balance and falls in patients with PD. | Excluded at full text screening (Did not grade evidence)
103 | 4 | PubMed: “Tai Chi and Hypertension” (21 systematic reviews in last 5 years); - Zhang W, Wang H, Xiong Z, Li C. Efficacy of Tai Chi exercise in patients with hypertension: systematic review and meta-analysis. Curr Probl Cardiol. 2024 Nov;49(11):102798. doi: 10.1016/j.cpcardiol.2024.102798.39208601; Conclusions: Tai Chi effectively lowers SBP levels in hypertension patients, however, did not show a statistically significant difference on DBP. (N=5 articles with 568 patients). | Excluded at full text screening (Did not grade evidence)
104 | 4 | - Guan Y, Hao Y, Guan Y, Wang H. Effects of Tai Chi on essential hypertension and related risk factors: A meta-analysis of randomized controlled trials. J Rehabil Med. 2020 May 11;52(5):jrm00057. doi: 10.2340/16501977-2683.32338292; Conclusion: Tai chi is an effective physical exercise in treating essential hypertension compared with control interventions. (Requires duration ≥ 12-weeks of tai chi training). | Excluded at full text screening (Did not grade evidence)
105 | 4 | PubMed: “Tai Chi and Metabolic Syndrome” (latest systematic review for a major health condition!); - Chau JPC, Leung LYL, Liu X, Lo SHS, Choi KC, Zhao J, Chiang HCY. Effects of Tai Chi on health outcomes among community-dwelling adults with or at risk of metabolic syndrome: A systematic review. Complement Ther Clin Pract. 2021 A ug;44:101445. doi: 10.1016/j.ctcp.2021.101445.34260997; Results: Twenty RCTs were included. One study involved adults with MetS, and the other 19 studies involved adults with at least one risk factor for MetS. Tai Chi was found to reduce waist circumference and increase high-density lipoprotein cholesterol in obese adults. Tai Chi also reduces waist circumference, body mass index, blood glucose level, insulin resistance, and increases the quality of life (QoL) in adults with elevated blood glucose/type 2 diabetes (T2DM). Among participants with hypertension, Tai Chi improves blood pressure, lipid profiles, anxiety, depression, and physical QoL.; Conclusions: Tai Chi may be effective for enhancing the physiological and psychosocial wellbeing of community-dwelling adults at risk of MetS. | Excluded at full text screening (In favor of a more informative review - Hypertension)
106 | 4 | PubMed: “Tai Chi and Osteoporosis” (6 systematic reviews in last 5 years); - Hou J, Mao H, Xie P, Cui Y, Rong M. The effect of different traditional Chinese exercises on bone mineral density in menopausal women: a systematic review and network meta-analysis. Front Public Health. 2024 Sep 12;12:1430608. doi: 10.3389/fpubh.2024.39328990; Results: Regarding BMD of femoral neck: TC [SMD = 1.24 (0.70, 1.78)], BA [SMD = 3.77 (1.98, 5.56)] were superior in increasing BMD of femoral neck relative to NEI. Regarding BMD of ward’s triangle: TC [SMD = 1.63 (1.09, 2.17)] was superior in increasing BMD of ward’s triangle relative to NEI. Regarding BMD of greater trochanter: TC [SMD = 0.98 (0.28, 1.68)] were superior in increasing BMD of greater trochanter relative to NEI. TC topped the SUCRA with BMD of lumbar L2-L4: 53.8, femoral neck: 74.9, ward’s triangle: 86.9 and greater trochanter: 77.7.; Conclusion: Four traditional Chinese exercises [Tai Chi (TC), Baduanjin (BDJ), Wuqinxi (WQX), Yijinjing (YJJ)] are all effective in partially improving bone mineral density (BMD) indicators in postmenopausal women, while TC was effective on all four BMD indicators, which seems to be recommended as the most suitable exercise modality for postmenopausal women. | Excluded at full text screening (Did not grade evidence)
107 | 4 | PubMed: “Tai Chi and Post-Stroke” (5 systematic reviews in the last 5 years); - Chen R, Guo Y, Kuang Y, Zhang Q. Effects of home-based exercise interventions on post-stroke depression: A systematic review and network meta-analysis. Int J Nurs Stud. 2024 Apr;152:104698. doi: 10.1016/j.ijnurstu.2024.104698.38290424; Results: In mind-body exercise interventions, Tai Chi was the most effective way to improve post-stroke depression (SUCRA: 99.4 %, Hedges’ g: −0.94, 95 % CI: −1.28 to −0.61).; Conclusions: With mind-body exercises, Tai Chi, shows promise as an effective treatment, but multicenter RCTs comparing specific exercises to no intervention are crucial, assessing not only efficacy but also dose, reach, fidelity, and long-term effects for real-world optimization. | Excluded at full text screening (Did not grade evidence)
108 | 4 | - Park M, Song R, Ju K, Seo J, Fan X, Ryu A, Li Y, Jang T. Effects of Tai Chi and Qigong on the mobility of stroke survivors: A systematic review and meta-analysis of randomized trials. PLoS One. 2022 Nov 17;17(11):e0277541. doi: 10.1371/journal.pone.0277541.36395145; Results: Meta-analysis of 27 randomized controlled trials with random-effects models indicated that Tai Chi (n=18) and Qigong (n=9) effectively improved mobility, specifically on the ability to walk (Hedges’g = 0.81), dynamic balance (Hedges’g = 1.04), and ADL (Hedges’g = 0.43). The effects of Tai Chi and Qigong were significant for short-term and long-term programs (Hedges’g 0.91 vs. 0.75), and when compared with active controls and no treatment group (Hedges’g 0.81 vs. 0.73).; Conclusion: Tai Chi and Qigong performed for 12 weeks or less were effective in improving the mobility of stroke survivors. | Excluded at full text screening (Did not grade evidence)
109 | 4 | PubMed: “Tai Chi and Sacropenia” (3 systematic Reviews in last 5 years); - Huang CY, Mayer PK, Wu MY, Liu DH, Wu PC, Yen HR. The effect of Tai Chi in elderly individuals with sarcopenia and frailty: A systematic review and meta-analysis of randomized controlled trials. Ageing Res Rev. 2022 Dec;82:101747. doi: 10.1016/j.arr.2022.101747.36223875; Conclusions: Our results demonstrated that patients with frailty or sarcopenia who practiced Tai Chi exhibited improved physical performance in the 30-second chair stand test, the Timed up and go test, number of falls and fear of falling. However, there was no difference in muscle mass, grip strength, gait speed, or Short Physical Performance Battery score between the Tai Chi and control groups. | Excluded at full text screening (Did not grade evidence)
110 | 4 | PubMed: Tai Chi and Safety (Adverse Events”); - Cui H, Wang QY, Pedersen M, Wang Q, Lv SJ, James D, Larkey L. The safety of tai chi: a meta-analysis of adverse events in randomized controlled trials. Contemp Clin Trials. 2019;82:85–92. doi: 10.1016/j.cct.2019.06.004.31229620; Conclusion: Findings indicate that TC does not result in more AEs than active and inactive control conditions, and produces fewer AEs than inactive control conditions for heart failure patients. | Excluded at full text screening (Did not grade evidence)
111 | 4 | - Yang GY, Hunter J, Bu FL, Hao WL, Zhang H, Wayne PM, Liu JP. Determining the safety and effectiveness of Tai Chi: a critical overview of 210 systematic reviews of controlled clinical trials. Syst Rev. 2022 Dec 3;11(1):260. doi: 10.1186/s13643-022-02100-5.36463306; Conclusions: Tai Chi was found to be generally safe and can be practiced at various levels of intensity by healthy adults, frail older adults, and people with chronic diseases. There was some evidence of beneficial physical, psychological, and quality of life outcomes from Tai Chi for a wide range of conditions. Given its multisystem effects, Tai Chi might be a suitable choice for those seeking a single intervention to help with numerous problems and symptoms. | Excluded at full text screening (Not a systematic review)
112 | 4 | PubMed: “Tai Chi and Sleep” (or Insomnia) (13 systematic reviews in last 5 years); - Hasan F, Tu YK, Lin CM, Chuang LP, Comparative efficacy of exercise regimens on sleep quality in older adults: A systematic review and network meta-analysis. Sleep Med Rev. 2022 Oct;65:101673. doi: 10.1016/j.smrv.2022.36087457; Conclusion: The results of this study support the claim that exercise can improve sleep quality in this population (older adults). | Excluded at full text screening (Did not grade evidence)
113 | 4 | - Li H, Chen J, Xu G, Duan Y, Huang D, Tang C, Liu J. The Effect of Tai Chi for Improving Sleep Quality: A Systematic Review and Meta-analysis. J Affect Disord. 2020 Sep 1;274:1102–1112. doi: 10.1016/j.jad.2020.05.076.32663938; Conclusions: Compared with non-therapeutic and other active treatments, Tai Chi has a positive effect on improving sleep quality. (N=20 RCTs with 1,703 patients) | Excluded at full text screening (Did not grade evidence)
114 | 4 | - Liu H, Liu S, Xiong L, Luo B. Effects of traditional Chinese exercise on sleep quality: A systematic review and meta-analysis of randomized controlled trials. Medicine (Baltimore). 2023 Nov 3;102(44):e35767. doi: 10.1097/MD.0000000000035767.37933009; Conclusion: TCE can improve sleep quality in specific populations in specific populations clinical applications. Tai chi should be considered first to improve sleep quality. (N=20 studies with several subgroups noting better effects, i.e., “patients with fibromyalgia, normal older adults, and non-Hodgkin lymphoma, chronic fatigue syndrome-like illness, knee osteoarthritis, nasopharyngeal carcinoma, pausimenia, insomnia, TCE could improve sleep quality.” | Excluded at full text screening (Did not grade evidence)
115 | 4 | PubMed: “Tai Chi and Social Support” (NEW TOPIC: Top systematic reviews in last 5 years); - Koren Y, Leveille S, You T. Tai Chi Interventions Promoting Social Support and Interaction Among O lder Adults: A Systematic Review. Res Gerontol Nurs. 2021 May-Jun;14(3):126–137. doi: 10.3928/19404921-20210325-02.34039148; (N = 10): PubMed, CINAHL, and PsycINFO databases were searched for studies eligible under the inclusion criteria: sample population aged ≥60 years and published between 1999 and 2019. Four articles reported on tai chi interventions with specific enhancements to promote social interaction and reported increased perceived social support (p < 0.05). Six studies evaluated social support outcomes of tai chi programs without specific modifications to promote social engagement. Four of the six traditional tai chi intervention studies reported improved social support (p < 0.05). Group tai chi interventions for older adults may increase social support and therefore further increase health benefits of tai chi exercise among this population. | Excluded at full text screening (Did not grade evidence)
116 | 4 | PubMed: “Tai Chi and Stress”; Kraft J, Waibl PJ, Meissner K. Stress reduction through taiji: a systematic review and meta-analysis. BMC Complement Med Ther. 2024 Jun 3;24(1):210. doi: 10.1186/s12906-024-04493-3.PMID: 38831412 Free PMC article38831412 | Published after our search, reviewed and excluded at full text screening (Did not grade evidence)
117 | 5 | Page 18 Evidence Map- Is evidence map possibly misleading because the size of the bubbles corresponds to the number of included studies, but does not take into account the size of the included studies? I.e., evidence might look stronger for a condition with 6 smaller studies vs 5 large studies? | Since we apply certainty of evidence ratings as an inclusion criteria to provide context for how readers should interpret the strength of evidence for a specific condition, the rating should have taken into account factors that affect strength of evidence such as size of included studies.
118 | 7 | In the “Synthesis” section, there appeared to be an error in that “Effect of massage therapy” was written, and I don’t think “massage” was meant to be there.; I would have liked the Discussion section to include “Strengths” about the paper, as well as its Limitations.; Some of the language in the “Limitations” section I found rather odd and questionable, with words like “suffer”, and then just a blanket statement about “judgment” as the basis for they went about the review. | We have made the change.“ Thank you for your suggestion. We have added “strengths” to the discussion section.
119 | 8 | pg ii line 57 Change- Jon Loesch to Jonathan Loesch; pg 5 line 9 Change Jon Loesch to Jonathan Loesch; pg 5 line 9–10 should Alison’s name be before my name Jonathan Loesch for consistency with pg ii. | We have made the changes.