# ABBREVIATIONS TABLE

Abbreviation: Definition
AHRQ: Agency for Healthcare Research & Quality
CIH: Complementary and integrative health
CINeMA: Confidence in network meta-analysis
EPC: Evidence Practice Center
ESP: Evidence Synthesis Program
GRADE: Grading of Recommendations, Assessment, Development and Evaluation
TCC: Tai chi chuan