# References

1 Simmons RF, P; Ghiron, L. Scaling up health services delivery: From pilot innovations to policies and programmes. World Health Organization;2008.
2 McCannon CJS, M. W.; Perla, R. J.. Planning for scale: A guide for designing large-scale improvement initiatives.. 2008.
3 OVretveit J, Bate P, Cleary P, . Quality collaboratives: lessons from research. Quality & safety in health care. 2002;11(4):345–351.12468695
4 Nolan K, Schall MW, Erb F, Nolan T. Using a framework for spread: The case of patient access in the Veterans Health Administration. Joint Commission journal on quality and patient safety. 2005;31(6):339–347.15999964
5 McCannon CJ, Perla RJ. Learning networks for sustainable, large-scale improvement. Joint Commission journal on quality and patient safety. 2009;35(5):286–291.19480384
6 McCannon CJ, Berwick DM, Massoud MR. The science of large-scale change in global health. Jama. 2007;298(16):1937–1939.17954547
7 Becher EC, Chassin MR. Improving the quality of health care: who will lead? Health affairs (Project Hope). 2001;20(5):164–179.
8 Arora S, Thornton K, Murata G, . Outcomes of treatment for hepatitis C virus infection by primary care providers. The New England journal of medicine. 2011;364(23):2199–2207.21631316
9 Asch SM, Kerr EA. Measuring What Matters in Health: Lessons from the Veterans Health Administration State of the Art Conference. Journal of general internal medicine. 2016;31: Suppl 1:1–2.
10 Organization WH. Bridging the “know–do” gap meeting on knowledge translation in global health.. Geneva: WHO;2006.
11 Commission P. Strengthening evidence-based policy in the Australian Federation, volume 2: background paper. Canberra: Productivity Commission;2010.
12 Zwarenstein M, Goldman J, Reeves S. Interprofessional collaboration: effects of practice-based interventions on professional practice and healthcare outcomes. The Cochrane database of systematic reviews. 2009(3):CD000072.19588316
13 In: Shojania KG, McDonald KM, Wachter RM, Owens DK, eds. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies (Vol. 1: Series Overview and Methodology). Rockville (MD) 2004.
14 French SD, Green S, Buchbinder R, Barnes H. Interventions for improving the appropriate use of imaging in people with musculoskeletal conditions. The Cochrane database of systematic reviews. 2010(1):CD006094.20091583
15 Schouten LM, Hulscher ME, van Everdingen JJ, Huijsman R, Grol RP. Evidence for the impact of quality improvement collaboratives: systematic review. BMJ (Clinical research ed). 2008;336(7659):1491–1494.
16 Bradley EH, Webster TR, Baker D, . Translating research into practice: speeding the adoption of innovative health care programs. Issue brief (Commonwealth Fund). 2004(724):1–12.
17 Steinbrook R. The potential of human papillomavirus vaccines. The New England journal of medicine. 2006;354(11):1109–1112.16540608
18 Berwick D. The science of improvement. JAMA - Journal of the American Medical Association. 2008;299(10):1182–1184.18334694
19 Norton WE, McCannon C, Schall MW, Mittman BS. A stakeholder-driven agenda for advancing the science and practice of scale-up and spread in health. [Internet Resource; Article]. 2012; http://www.implementationscience.com/content/7/1/118 http://www.implementationscience.com/content/7/1/118 Materials specified: Item Resolution URL Instruction: Put this Resolution URL in a web browser toview this item.
20 Aarons GA, Sklar M, Mustanski B, Benbow N, Brown CH. “Scaling-out” evidence-based interventions to new populations or new health care delivery systems. Implementation science: IS. 2017;12(1):111.28877746
21 Services DoHaH. Dissemination and implementation research in health (R01) NIH funding opportunity: PAR-16-238. In: NIH grant funding opporutnities; 2016:2017.
22 Lanham HJ, Leykum LK, Taylor BS, McCannon CJ, Lindberg C, Lester RT. How complexity science can inform scale-up and spread in health care: understanding the role of self-organization in variation across local contexts. Social science & medicine (1982). 2013;93:194–202.22819737
23 Milat AJ, Bauman A, Redman S. Narrative review of models and success factors for scaling up public health interventions. Implementation science: IS. 2015;10:113.26264351
24 Milat AJ, King L, Newson R, . Increasing the scale and adoption of population health interventions: experiences and perspectives of policy makers, practitioners, and researchers. Health research policy and systems. 2014;12:18.24735455
25 Mangham LJ, Hanson K. Scaling up in international health: what are the key issues? Health policy and planning. 2010;25(2):85–96.20071454
26 Cooley LK, R. Scaling Up-From Vision to Large-Scale Change: A Management Framework for Practitioners. Washington D.C.: Management Systems International;2006.
27 Hanson K, Cleary S, Schneider H, Tantivess S, Gilson L. Scaling up health policies and services in low- and middle-income settings. BMC health services research. 2010;10: Suppl 1:I1.20594366
28 Organization WH. ExpandNet: nine steps for developing a scaling-up strategy. Geneva: WHO;2010.
29 Massoud MRN, G.A.; Nolan, K.; Schall, M.W.; Sevin, C. A Framework for Spread: From Local Improvements to System-Wide Change. IHI Innovation Series White Paper Institute for Healthcare Improvement. 2006.
30 Hanson K, Ranson, M. K., Oliveira‐Cruz, V., Mills, A. Expanding access to priority health interventions: a framework for understanding the constraints to scaling‐up.. Journal of International Development: The Journal of the Development Studies Association. 2003;15(1):1–14.
31 Simmons RS, J. Scaling up health service innovations: a framework for action.. Scaling up health service delivery. 2007;1(30).
32 Subramanian S, Naimoli J, Matsubayashi T, Peters DH. Do we have the right models for scaling up health services to achieve the Millennium Development Goals? BMC health services research. 2011;11:336.22168915
33 Yamey G. Scaling up global health interventions: a proposed framework for success. PLoS medicine. 2011;8(6):e1001049.21738450
34 Yano EM, Green LW, Glanz K, . Implementation and spread of interventions into the multilevel context of routine practice and policy: implications for the cancer care continuum. Journal of the National Cancer Institute Monographs. 2012;2012(44):86–99.22623601
35 Stetler CB, Mittman BS, Francis J. Overview of the VA Quality Enhancement Research Initiative (QUERI) and QUERI theme articles: QUERI Series. Implementation science: IS. 2008;3:8.18279503
36 Rogers EM. Diffusion of Innovations. Simon and Schuster; 2010.
37 Robert G, Morrow E, Maben J, Griffiths P, Callard L. The adoption, local implementation and assimilation into routine nursing practice of a national quality improvement programme: the Productive Ward in England. Journal of clinical nursing. 2011;20(7–8):1196–1207.21320218
38 Heinrich j. Cultural transmission and the diffusion of innovations: Adoption dynamics indicate that biased cultural transmission is the predominate force in behavioral change. American Antrhopologist. 2001;103(4):992–1013.
39 Greenhalgh T, Robert G, Macfarlane F, Bate P, Kyriakidou O. Diffusion of innovations in service organizations: systematic review and recommendations. The Milbank quarterly. 2004;82(4):581–629.15595944
40 Grumbach K, Lucey CR, Johnston SC. Transforming from centers of learning to learning health systems: the challenge for academic health centers. Jama. 2014;311(11):1109–1110.24643597
41 Lowes LPH, G.; Newmeyer, A.; Embi, P.; Yin, H.; Smoyer, W. Learn From Every Patient: implementation and early results of a learning health system. Developmental Medicine and Child Neurology. 2016.
42 Smoyer WE, Embi PJ, Moffatt-Bruce S. Creating Local Learning Health Systems: Think Globally, Act Locally. Jama. 2016;316(23):2481–2482.27997662
43 Tong A, Sainsbury P, Craig J. Consolidated criteria for reporting qualitative research (COREQ): a 32-item checklist for interviews and focus groups. International journal for quality in health care: journal of the International Society for Quality in Health Care. 2007;19(6):349–357.
44 (VSSC) VSSC. The Strategic Analytics for Improvement and Learning (SAIL) Value Model (a.k.a VA-TR) Documentation. In: Department of Veterans Affairs.
45 Averill JB. Matrix analysis as a complementary analytic strategy in qualitative inquiry. Qualitative health research. 2002;12(6):855–866.12109729
46 Miles MBH, A.M.; Saldana, J. Qualitative Data Analysis. A Methods Sourcebook. 3rd ed. Thousand Oaks, CA: Sage Publications Ltd; 2014.
47 Hamilton A. Qualitative Methods in Rapid Turn-Around Health Services Research. In: VA HSR&D National Cyberseminar Series: Spotlight on Women’s Health; 2013.
48 Liu VX, Morehouse JW, Baker JM, Greene JD, Kipnis P, Escobar GJ. Data that drive: Closing the loop in the learning hospital system. Journal of hospital medicine. 2016;11: Suppl 1:S11–s17.27805797
49 Della Penna R, Martel H, Neuwirth EB, . Rapid spread of complex change: a case study in inpatient palliative care. BMC health services research. 2009;9:245.20040099
50 Psek WA, Stametz RA, Bailey-Davis LD, . Operationalizing the learning health care system in an integrated delivery system. EGEMS (Washington, DC). 2015;3(1):1122.
51 Harris JG, Bingham CA, Morgan EM. Improving care delivery and outcomes in pediatric rheumatic diseases. Current opinion in rheumatology. 2016;28(2):110–116.26780426
52 Elson SL, Hiatt RA, Anton-Culver H, . The athena breast health network: Developing a rapid learning system in breast cancer prevention, screening, treatment, and care. Breast Cancer Research and Treatment. 2013;140(2):417–425.23887672
53 Boustani MA, Frame A, Munger S, . Connecting research discovery with care delivery in dementia: the development of the Indianapolis Discovery Network for Dementia. Clinical interventions in aging. 2012;7:509–516.23204843
54 Septimus E, Hickok J, Moody J, . Closing the Translation Gap: Toolkit-based Implementation of Universal Decolonization in Adult Intensive Care Units Reduces Central Line-associated Bloodstream Infections in 95 Community Hospitals. Clinical infectious diseases: an official publication of the Infectious Diseases Society of America. 2016;63(2):172–177.27143669
55 Clark SR, Wilton L, Baune BT, Procter N, Hustig H. A state-wide quality improvement system utilising nurse-led clinics for clozapine management. Australas Psychiatry. 2014;22(3):254–259.24811715
56 Hub VPI. http://vhaindwebsim.v11.med.va.gov/hub2/pi/.
57 Elnahal SML, Patrick; Ippolito, Andrea. VA creates a “Shark Tank” to identify ideas to better serve Veterans. In. VAntage Point 2016.
58 VHA Access to Care Initiative. http://vhaindwebsim.v11.med.va.gov/hub2/atc/.
59 Lorig KR, Hurwicz ML, Sobel D, Hobbs M, Ritter PL. A national dissemination of an evidence-based self-management program: a process evaluation study. Patient education and counseling. 2005;59(1):69–79.16198220
60 Rogers KM, Childers DJ, Messler J, Nolan A, Nickel WK, Maynard GA. Glycemic control mentored implementation: creating a national network of shared information. Joint Commission journal on quality and patient safety. 2014;40(3):111–118.24730206
61 Damschroder LJ, Lowery JC. Evaluation of a large-scale weight management program using the consolidated framework for implementation research (CFIR). Implementation science: IS. 2013;8:51.23663819
62 Gardner KL, Dowden M, Togni S, Bailie R. Understanding uptake of continuous quality improvement in Indigenous primary health care: lessons from a multi-site case study of the Audit and Best Practice for Chronic Disease project. Implementation science: IS. 2010;5:21.20226066
63 Lustig A, Ogden M, Brenner RW, Penso J, Westrich KD, Dubois RW. The Central Role of Physician Leadership for Driving Change in Value-Based Care Environments. Journal of managed care & specialty pharmacy. 2016;22(10):1116–1122.27668560
64 Denis JL, Hebert Y, Langley A, Lozeau D, Trottier LH. Explaining diffusion patterns for complex health care innovations. Health care management review. 2002;27(3):60–73.12146784
65 Patel H, Wilson E, Vizzotti C, Parston G, Prestt J, Darzi A. Argentina’s Successful Implementation Of A National Human Papillomavirus Vaccination Program. Health affairs (Project Hope). 2016;35(2):301–308.26858384
66 Ilott I, Gerrish K, Pownall S, Eltringham S, Booth A. Exploring scale-up, spread, and sustainability: an instrumental case study tracing an innovation to enhance dysphagia care. Implementation science: IS. 2013;8:128.24168667
67 Blue-Howells JH, Clark SC, van den Berk-Clark C, McGuire JF. The U.S. Department of Veterans Affairs Veterans Justice programs and the sequential intercept model: case examples in national dissemination of intervention for justice-involved veterans. Psychological services. 2013;10(1):48–53.22924802
68 Box TL, McDonell M, Helfrich CD, Jesse RL, Fihn SD, Rumsfeld JS. Strategies from a nationwide health information technology implementation: the VA CART story. Journal of general internal medicine. 2010;25: Suppl 1:72–76.
69 Goetz MB, Hoang T, Bowman C, . A System-wide Intervention to Improve HIV Testing in the Veterans Health Administration. J Gen Intern Med 2008;23(8):1200–1207.18452045
70 Mills PD, Weeks WB, Surott-Kimberly BC. A multihospital safety improvement effort and the dissemination of new knowledge. Joint Commission journal on quality and safety. 2003;29(3):124–133.12635428
71 Resnick SG, Rosenheck R. Dissemination of supported employment in Department of Veterans Affairs. Journal of rehabilitation research and development. 2007;44(6):867–877.18075943
72 Resnick SG, Rosenheck RA. Scaling up the dissemination of evidence-based mental health practice to large systems and long-term time frames. Psychiatric services (Washington, DC). 2009;60(5):682–685.
73 Rubenstein LV, Chaney EF, Ober S, . Using evidence-based quality improvement methods for translating depression collaborative care research into practice. Families, systems & health: the journal of collaborative family healthcare. 2010;28(2):91–113.
74 Curran GM, Pyne J, Fortney JC, . Development and implementation of collaborative care for depression in HIV clinics. AIDS care. 2011;23(12):1626–1636.21714689
75 Luck J, Hagigi F, Parker LE, Yano EM, Rubenstein LV, Kirchner JE. A social marketing approach to implementing evidence-based practice in VHA QUERI: the TIDES depression collaborative care model. Implementation science: IS. 2009;4:64.19785754
76 Yano EM. A Partnered Research Initiative to Accelerate Implementation of Comprehensive Care for Women Veterans The VA Women’s Health CREATE. Medical Care. 2015;53(4):S10–S14.25767962
77 Best A, Berland A, Herbert C, . Using systems thinking to support clinical system transformation. Journal of health organization and management. 2016;30(3):302–323.27119388
78 Cheyne H, Abhyankar P, McCourt C. Empowering change: realist evaluation of a Scottish Government programme to support normal birth. Midwifery. 2013;29(10):1110–1121.23968777
79 Clarke CL, Keyes SE, Wilkinson H, . Organisational space for partnership and sustainability: lessons from the implementation of the National Dementia Strategy for England. Health & social care in the community. 2014;22(6):634–645.25243927
80 Hendrich A, Tersigni AR, Jeffcoat S, Barnett CJ, Brideau LP, Pryor D. The Ascension Health journey to zero: lessons learned and leadership. Joint Commission journal on quality and patient safety. 2007;33(12):739–749.18200899
81 Hung D, Gray C, Martinez M, Schmittdiel J, Harrison MI. Acceptance of lean redesigns in primary care: A contextual analysis. Health care management review. 2017;42(3):203–212.26939032
82 Kellogg KC, Gainer LA, Allen AS, Sullivan TO, Singer SJ. An intraorganizational model for developing and spreading quality improvement innovations. Health care management review. 2017;42(4):292–302.27428788
83 Lennon MR, Bouamrane MM, Devlin AM, . Readiness for Delivering Digital Health at Scale: Lessons From a Longitudinal Qualitative Evaluation of a National Digital Health Innovation Program in the United Kingdom. Journal of medical Internet research. 2017;19(2):e42.28209558
84 Marshall M, Mountford J, Gamet K, . Understanding quality improvement at scale in general practice: a qualitative evaluation of a COPD improvement programme. Br J Gen Pract. 2014;64(629):E745–E751.25452538
85 Noyes J, Lewis M, Bennett V, Widdas D, Brombley K. Realistic nurse-led policy implementation, optimization and evaluation: novel methodological exemplar. Journal of advanced nursing. 2014;70(1):220–237.23713840
86 Ovseiko PV, O’Sullivan C, Powell SC, Davies SM, Buchan AM. Implementation of collaborative governance in cross-sector innovation and education networks: evidence from the National Health Service in England. BMC health services research. 2014;14:552.25380727
87 Schmittdiel JA, Dlott R, Young JD, Rothmann MB, Dyer W, Adams AS. The Delivery Science Rapid Analysis Program: A Research and Operational Partnership at Kaiser Permanente Northern California. Learning health systems. 2017;1(4).
88 Azar J, Adams N, Boustani M. The Indiana University Center for Healthcare Innovation and Implementation Science: Bridging healthcare research and delivery to build a learning healthcare system. Zeitschrift fur Evidenz, Fortbildung und Qualitat im Gesundheitswesen. 2015;109(2):138–143.
89 Cyr J, Paige P, Paige P, Fisher D. Sustaining and spreading reduced door-to-balloon times for ST-segment elevation myocardial infarction patients. Joint Commission journal on quality and patient safety. 2009;35(6):297–306.19565689
90 Duckers ML, Groenewegen PP, Wagner C. Quality improvement collaboratives and the wisdom of crowds: spread explained by perceived success at group level. Implementation science: IS. 2014;9:91.25318971
91 Johnson LC, Melmed GY, Nelson EC, . Fostering Collaboration Through Creation of an IBD Learning Health System. The American journal of gastroenterology. 2017;112(3):406–408.28195179
92 Kwon S, Florence M, Grigas P, . Creating a learning healthcare system in surgery: Washington State’s Surgical Care and Outcomes Assessment Program (SCOAP) at 5 years. Surgery. 2012;151(2):146–152.22129638
93 Lannon CM, Peterson LE. Pediatric collaborative improvement networks: background and overview. Pediatrics. 2013;131: Suppl 4:S189–195.23729759
94 Ramsey LB, Mizuno T, Vinks AA, Margolis PA. Learning Health Systems as Facilitators of Precision Medicine. Clinical pharmacology and therapeutics. 2017;101(3):359–367.27984650
95 Rocker GM, Amar C, Laframboise WL, Burns J, Verma JY. Spreading improvements for advanced COPD care through a Canadian Collaborative. Int J Chronic Obstr Pulm Dis. 2017;12:2157–2164.
96 van Schendel RV, van El CG, Pajkrt E, Henneman L, Cornel MC. Implementing noninvasive prenatal testing for aneuploidy in a national healthcare system: global challenges and national solutions. BMC health services research. 2017;17(1):670.28927451
97 Grayson MLR, P.L.; Cruickshank, M.; Bear, J.L.; Gee, C.A.; Hughes, C.F.; Johnson, P.D.; McCann, R.; McMillan, A.J. Outcomes from the first 2 years of the Australian National Hand Hygiene Initiative. The Medical journal of Australia. 2011;195:615–619.22107015
98 McMullen H, Griffiths C, Leber W, Greenhalgh T. Explaining high and low performers in complex intervention trials: a new model based on diffusion of innovations theory. Trials. 2015;16:242.26026849
99 Parv L, Kruus P, Motte K, Ross P. An evaluation of e-prescribing at a national level. Informatics for health & social care. 2016;41(1):78–95.25115948
100 Pearce C, Bartlett J, McLeod A, Eustace P, Amos R, Shearer M. Effectiveness of local support for the adoption of a national programme--a descriptive study. Informatics in primary care. 2014;21(4):171–178.