# Summary and Discussion

## Summary

### What Does Large Magnitude Scale-up and Spread Look Like?

#### Breaking down the national spread process

After working with innovators to test and pilot the initiative and then working with early adopters to test scale-up and spread strategies, activities described in our data split the final phase of full-scale spread into 2 parts with distinct strategies. The first part of the full-scale spread, which we are calling the “mass broadcast” phase, uses strategies intended to reach a maximal audience. The second part of the full-scale spread phase, which we are calling the “re-personalize” phase, returns to using strategies more often employed in the first 2 phases of the spread process.

#### Macro models

We identified 3 distinct macro models to describe the organization or infrastructure of spread efforts in the 52 included publications. These included spread efforts that embedded scale-up or spread within a system of care (n=29), collaboratives or exchanges to support the spread of multiple initiatives within a specific topic area (n=14), and initiative-specific spread efforts (n=9).

#### Preconditions to consider in large-magnitude scale-up

Several factors repeatedly arose throughout the QUERI interviews, SAIL interviews, and literature as crucial information to gather prior to engaging in large magnitude scale-up. It is crucial that scale-up initiators gather information on who will need to be involved at each site and identify context-specific that will be align with the goals of the spread.

#### VA preconditions and existing networks for spread

In addition to building networks de novo for a specific collaborative or exchange, spread efforts can also leverage existing networks in a similar model to collaboratives or exchanges. To better understand the existing conditions in VA that could facilitate spread efforts, we used data from the SAIL improver interviews. This information-seeking almost always occurred after working on homegrown solutions and analyzing local priorities and challenges. Once specific initiatives or issues had been identified, SAIL improvers sought information related to that particular area of interest. Existing sources of spread in the VA include peer to peer connections, existing VA hubs of information, central office expertise, and some non-VA entities.

### Considerations and Strategies for Working with Hard-to-engage Sites

We drew from the QUERI spread project papers and interviews, as well as from the 18 publications we identified as either providing descriptions of hard-to-engage sites (n=11) or additionally providing descriptions of strategies used with these hard-to-engage sites after identifying/describing them (n=7). The proportion of hard-to-engage sites was small, and the phrase “N-of-1” was used repeatedly throughout the QUERI interviews to describe experiences working with hard-to-engage sites. While descriptions of hard-to-engage sites often portrayed challenges, a number of beneficial characteristics also warrant mention due to their repeated appearance. Hard-to-engage sites may have low bandwidth or limited resources, local innovations or homegrown solutions that present competition for an innovation, or competing priorities that do not overlap with the priorities of a spread initiative. While these were among the common challenges hard-to-engage-sites might face, a number of potential benefits were also highlighted: a healthy skepticism can lead to collaboration and potential innovation improvement, hard-won engagement that is slow to come may be more durable in the long-term, and low performing sites can sometimes be easier to engage since their priorities are in alignment with a spread initiative’s goals.

Since hard-to-engage sites are highly variable in their needs, QUERI interviewees recommended “a flexible, tailored approach to one [site] at a time.” Useful strategies for hard-to-engage sites, as highlighted in the most salient themes from the literature and interviews, include facilitation, creating a web of support, establishing peer to peer communication, allowing sites to kick the tires of an innovation, tackling upstream issues, increasing visibility with multiple levels of leadership, utilizing a hard core with soft periphery model of innovation, maintaining engagement with non-adopter sites, and framing the message to initiate positive and helpful working relationships.

## Limitations

The primary challenge for topics without a specific disease or therapy is identifying relevant literature. Because terminology related to scale and spread is evolving, there are no reliable, standardized terms for systematically searching databases for literature related to this topic, so relevant literature might have been missed. In addition, our use of key informant interviews was limited to informants discussing experiences within the VA system. For the scope of this report we limited to VA-relevant experiences because the findings are intended to be applied in VA settings. However, lessons from stakeholders outside the VA may have provided more diverse lessons which could be applicable, especially from other large healthcare systems such as the National Health Service in the UK.

There are several challenges common in literature synthesis studies that also affect this review. Studies often do not describe the types of details needed for a particular review. Such is the case here for studies that have conducted large magnitude scale initiatives, especially related to hard-to-engage sites. While data limitations prevent us from performing a statistical test of publication bias, such bias is almost certainly present, as less-than-successful spread efforts are unlikely to be written up for publication. Even successful spread may not be written into reports or materials that would be identified by literature synthesis techniques, and these would also be missed in our process. We would expect that there have been more than the 52 spread efforts we identified in our review, and we do not have information about the contexts or success of these unpublished spread efforts. For instance, multiple VA QUERI projects we identified through our search of the QUERI database did not have any publications associated with their entries.

A key assumption in this report and in much of the scale-up and spread work included was that a given initiative was broadly desirable or necessary, but there are initiatives and programs that don’t work well for every site. It is worth noting that the best decision for a given site might be to say no to a change initiative, particularly in situations where there is low bandwidth, a large set of competing demands, or a homegrown solution that works. Virtually any change initiative is stressful and disruptive, and there are certainly circumstances where the work would not be beneficial in the broader context of a site.

While scale-up and spread are often used interchangeably, they are distinct, as Ilott and colleagues differentiate in describing “scale-up” as typically relying on a planned top-down strategy to diffuse innovation, while “spread” is related to horizontal diffusion of innovations.^66^ The distinctions are nuanced but important when attempting to identify strategies and moderators of increasing use of an innovation. In the context of this report, we use these definitions when possible. However, because the original sources often did not distinguish between these terms, or necessarily provide details that would allow us to distinguish which of these terms best fit, our resulting language also lacks definitional clarity between scale-up and spread.

## Research Gaps and Recommendations for Future Research

Expanding upon the study of scale-up and spread in implementation science, future work moving from the early stages of scale-up and spread into a more detailed description of the full spread phase could focus on testing different strategies for large magnitude spread and for reaching hard-to-engage sites in particular. This effort could also include better documentation of tailoring or adaptations that occur towards later stages of spread efforts, including specific approaches and strategies used to engage hard-to-engage sites.

The relationship between the 3 macro models described in this report, or the organization of spread efforts more generally, and particular strategies and target audiences was difficult to describe with the literature we identified. For instance, no collaboratives described strategies for hard-to-engage-sites, so it is unknown how hard-to-engage sites might fit into this model. While theoretically any macro model could use strategies to work with hard-to-engage groups, embedded system spread efforts may have more incentive to do so, since they were most often describing their work with hard-to-engage sites.

In addition, defining the overlap between low performing and late adopting or hard-to-engage adopters would aid in better tailoring strategies for both groups. While there may be substantial overlap, some distinctions were also made, particularly in the QUERI interviews. For instance, high performing sites may be hard to engage if they do not have a need for the intervention, and low performing sites, in contrast, may have needs that align with an intervention and thus may be eager to engage. This work could be done both empirically, but also conceptually.

## Recommendations for Future Scale-up/Spread Efforts

Here we highlight some recommendations for future work in implementing scale-up or spread efforts.

- Before engaging sites, take time to understand the salient local factors (see Figure 5) and determine if there are existing networks that could be leveraged (see Figure 6).
- In organizing a spread or scale-up effort, consider the various models infrastructure could take and how these may impact the effort.
- Using the knowledge of local sites that has been gathered, identify potential challenges or characteristics of these sites that might make them hard-to-engage and tailor strategies appropriately.

## Conclusions

Low performers and hard-to-engage audiences are most in need of engagement when spreading innovations intended to standardize practice or improve quality of care, but they were understudied in the identified literature on large magnitude spread efforts, which can be embedded spread within a system of care, collaboratives or exchanges, or initiative-specific spread efforts. Variations in care delivery will require a better understanding of how to work with low performer and hard-to-engage groups. Hard-to-engage sites can be highly variable in terms of the challenges or barriers they face, which can include low bandwidth, different priorities from a spread effort’s intended goals, and homegrown solutions that compete with innovations being spread. For the myriad of individual factors these sites face, bundles of engagement strategies that are more personalized and intensive can help spread initiators reach these groups. More testing of strategies to use with these groups, as well as documentation of adaptations or tailoring large magnitude spread efforts make in engaging different groups of adopters, is needed.