# Results

## Literature Flow

We identified 1,919 potentially relevant citations, of which 964 were included at title screening. From these, a total of 657 abstracts were excluded. Excluded abstracts were categorized as not healthcare delivery (n=115), low income country (n=22), learning health system but not spread (n=109), discussion of spread (n=121), small roll-out (n=66), or otherwise not relevant to the topic of spread (n=224). The other 307 abstracts were included and obtained as full text publications. The 255 publications that were excluded at full-text review were categorized as exclusions for the following reasons: learning health system but not spread (n=62), discussion of spread (n=45), small rollout (n=20), full text unavailable (n=22), not healthcare delivery (n=7), low income country (n=3), duplicate (n=1), or otherwise not relevant to the topic of spread (n=95). This final group included studies of piloting or initial testing of interventions (n=53), pre-implementation analyses with no implementation component (n=38), and other topics not relevant to spread (eg, medical education programming, n=4). A full list of excluded studies from the full-text review is included in Appendix F. A total of 52 publications were identified at full-text review as meeting inclusion criteria and contributed to our final sample (See Figure 2 for literature flow). The included studies discussed spread strategies for hard-to-engage sites (n=7), described hard-to-engage sites but did not discuss specific strategies (n=11), and discussed spread strategies more generally (n=37). Descriptions of publications in this latter group, which are discussed in less detail throughout the report, are available in Evidence Tables (Appendix G).

Figure 2 Literature Flow Chart

## What does Large Magnitude Scale-up and Spread Look Like?

As the QUERI pipeline^35^ and IHI Phases of Scale-up suggest,^1^ large magnitude scale-up or spread is a planned and organized effort with various phases. We first propose additional specifications to the phases proposed by these frameworks to account for hard-to-engage sites. The organization or infrastructure supporting these efforts can take multiple forms or models, and here we highlight the 3 macro models we identified. We then discuss factors that repeatedly arose throughout the interviews and literature as crucial information to know prior to engaging in large magnitude scale-up. Finally, we discuss VA preconditions and existing networks for spread that currently facilitate diffusion throughout the system.

### Breaking Down the National Scale-up or Spread Process

Of the 52 included publications, 7 publications went beyond discussing their overall spread approach to specifically describe strategies they used to work with hard-to-engage sites. Themes from these publications, as well as themes from the QUERI interviews, were combined into a synthesis related to how hard-to-engage sites relate to the overall process of scale-up or spread (see Figure 3).

The first 2 phases have been described by the QUERI pipeline^35^ and IHI Phases of Scale-up,^1^ and our data support their descriptions of these phases. Whether the earliest stage includes using an evidence-based innovation or developing a new idea, this phase includes small-scale testing or piloting with direct involvement of the team at the initial site or small number of sites. This work requires personalized, first-hand contact and typically builds relationships among those developing, implementing, and evaluating the initiative. As the phases of scale-up and spread progress, the breadth of contact across sites is emphasized over the depth of contact at any individual site.

While our data support much of what these frameworks describe, activities described in our data split the final phase of “going full-scale”^1^ or “national roll-out effort”^9^ into 2 parts with distinct strategies. The first part of the full-scale spread, which we are calling the “mass broadcast” phase, uses strategies intended to reach maximal audience. This first part seems to align with the breadth of contact suggested by the frameworks. However, the second part of the full-scale spread phase, which we are calling the “re-personalize” phase, returns to using strategies more often employed in the first phase of the spread process. This final part of the scale-up or spread process is focused on those hard-to-engage sites that did not engage with the “mass broadcast” strategies or approach.

Figure 3 Large Magnitude Spread Process

The “mass broadcast” phase of large magnitude spread, in publications and interviews alike, was nearly always described as beginning with strong top-down support, as one interviewee notes:

“I think having a strong partnership with [national leaders] was a critical factor in making this happen and getting the facilities, the units involved as well because they knew that we had the backing of the National Program Office to make this happen.”

This could take the form of summits with all top-level leadership, for example: “… senior regional leadership identified reducing sepsis mortality as a key performance improvement goal… The effort was launched… at a Sepsis Summit.”^48^ Other more formal arrangements like an official mandate or policy change were also used, with mandates present in nearly every QUERI interview like the following: “the… Directive, that was a top-down strategy where the government said everybody must do this.” This was typically effective during the “mass broadcast” phase of a national spread effort, and in garnering this leadership support it was often very important to have evidence of success from the innovators and early adopter groups, as noted by one national spread initiative of inpatient palliative care: “the evidence behind the model, demonstrated by the randomized trial, was an important factor promoting its spread.”^49^ While these and other mass-scale approaches were helpful in amplifying the magnitude of spread to the majority audiences, typically additional strategies were needed for the hard-to-engage group, which are discussed as a separate phase below.

The “re-personalize” phase returns to an approach used in earlier phases, which reflects a return to more personalized and intensive engagement. In experimenting with and testing strategies early in the spread process, spread initiators are often engaging sites much more heavily to collect data, refine approaches, and learn from their early experiences. In some ways, the strategies recommended for hard-to-engage sites tend to reflect a return to this increased connection with sites, and later sections of this report discuss specific strategies for hard-to-engage sites in greater detail.

### Macro Models

We identified 3 distinct macro models to describe the organization or infrastructure of spread efforts in the 52 included publications. These included spread efforts that embedded scale-up or spread within a system of care (n=29), collaboratives or exchanges to support the spread of multiple initiatives within a specific topic area (n=14), and initiative-specific spread efforts (n=9). Figure 4 displays this distribution of publications, as well as an example for each type of model and key features.

Figure 4 Macro Model Distributions and Descriptions

The 29 publications classified as embedded within systems either discussed specific projects within these systems or the system itself, which had spread infrastructure to tackle high priorities within the institution. Some, like Geisinger Learning Health System,^50^ specifically use the learning health system term, whereas others describe similar attributes including system-wide infrastructure, shared priorities and agenda setting, and initiatives or practices aimed at supporting the larger system priorities. The VA, Kaiser Permanente Northern California, and the National Health Service in the UK are all examples of systems with publications describing embedded spread efforts. These organizations typically have shared infrastructure, like an electronic health record, and a clear number of sites that fall within the scope of any particular spread effort.

Collaboratives or exchanges, which were described in 14 included publications, span multiple organizations. They share a topic or priority area, such as pediatric rheumatology,^51^ or breast health,^52^ and may be defined by a particular locality, like the Indianapolis Discovery Network for Dementia.^53^ The organizations typically receive little to no incentive to participate, choosing to opt-in voluntarily. The intention of these networks is bi-directional exchange, so organizations could be described as learning together simultaneously.

The final model, initiative-specific spread, most aligns with the classic models described in the frameworks described earlier.^1,35^ In this model the initiative or practice in question has been developed and is now moving to new sites. While it may be a bundle or toolkit, there is a defined set or package that is being pushed out. The spread activities are often funded by the origin site or other sources external to the adopter sites. While this model could include smaller spread efforts, this review limited spread magnitude to include 10 or more sites, and the identified publications described spread efforts that were usually regional or national in scope. Examples include the scale-up of a universal decolonization toolkit to 95 hospitals across the United States,^54^ as well as a state-wide spread of a clozapine management system in Australia.^55^

### Preconditions to Consider in Large Magnitude Scale-up

This section describes factors that repeatedly arose throughout the interviews as crucial information to gather prior to engaging in large magnitude scale-up. This was corroborated by the types of issues raised in the 11 publications that described hard-to-engage sites. Initiators of scale-up should not assume that all sites have similar conditions, and understanding salient preexisting factors was consistently highlighted across both sets of interviews and the included publications. Initiators of scale-up efforts often know what they are scaling, when they would want to scale, and where they would like to scale in order to define their scope of work. But having more knowledge about the sites is also crucial to planning a scale-up effort. Gathering more information on who will need to be involved locally and local reasons why sites may (or may not) align with the goals of the scale-up is central information in the planning stages of large magnitude scale-up (see Figure 5). Any effort to engage a site should consider this information-gathering in the early formative stages, regardless of variations in later plans.

Figure 5 Preconditions for Scale-up

### VA Preconditions and Existing Networks for Spread

In addition to building networks de novo for a specific collaborative or exchange, spread efforts can also leverage existing networks in a similar model to collaboratives or exchanges. To better understand the existing conditions in VA that could facilitate spread efforts, we used data from the SAIL improver interviews. The VA interviewees looking to improve their SAIL measures described several sources from which they sought information on potential improvement methods (see Figure 6). We describe here the way participants use these sources of information, which parallels the preconditions discussed for scale-up initiators, in that here we discuss the preconditions individual sites take prior to engaging in spread.

This information-seeking almost always occurred after working on homegrown solutions and analyzing local priorities and challenges. Once specific initiatives or issues had been identified, SAIL improvers sought information related to that particular area of interest. Figure 6 below highlights this process, as well as sources of information and assistance, as described by the SAIL improver key informant interviews. These sources of information and assistance all facilitate the spread of ideas, interventions, and information.

Figure 6 Local Preconditions Prior to Engaging in Spread

### Peer to Peer Connections

SAIL improvers very often described reaching out to other sites to hear about their peers’ experiences. While these connections would sometimes happen on VA Pulse or through cold-calling, the VISNs often facilitated this connection by highlighting sites with interesting or successful approaches and holding VISN-wide meetings or calls: “the VISN was helpful in that they really did organize… forums where best practices can be shared but more importantly it gave key folks in our facility [a venue] to present their work.” Sites particularly wanted connections with other sites that seemed similar to their own sites or to “see where those other high performing facilities are and then we need to reach out to them.”

“we have the ability to reach out and get some great best practices from the other sites”

#### Existing VA Hubs of Information

While VA Pulse was most often endorsed, other hubs including the VA Performance Improvement Hub,^56^ the VHA Shark Tank Competition,^57^ and the VHA Access to Care Initiative Hub^58^ were also mentioned by key informants. One site shared the following strategy for staying connected to a variety of hubs:

“We have link to all those [hubs] listed in our … project repository SharePoint site, so… if somebody wants to get an idea on how to improve patient cancelations, they can go to the VA Performance [Improvement Hub], or they can go to the VHA Access to Care Initiative and search for that. We also use VA Pulse quite a bit actually, where we’ll go on there and we’ll do a search and look for specific project assistance”.

Another interviewee highlighted a challenge of finding information within the VA:

“It’s very hard in this huge healthcare system to find these toolkits… if your computer ever crashes, you’re in trouble because once you find the link you’ve gotta bookmark it. There’s no real fully-organized place for that stuff… it shouldn’t be that hard to find that stuff. And sometimes I find it and then I can’t find it again.”

#### Central Office support

SAIL improvers would proactively contact national program offices, like the Office of Nursing Services or the Office of Mental Health for specific questions. These often included questions about how a particular metric was constructed, to see if there were best practices or advice that office could share about a particular metric, or to be connected with a site that had best practices.

Key informants also highlighted the usefulness of having a site visit or “deep dive” into the statistics and measures of the SAIL program with Dr. Almenoff, Director of Organizational Excellence in the VA Secretary’s Office. There were also multiple sites who used the SAIL mini-series lectures, which were so popular that “things actually started to get to the point where you need to register the moment that they came out and they ran out of spots… we kept all of the information, kept good records.”

#### Non-VA entities

To a lesser extent, informants named organizations including the Institute for Healthcare Improvement (IHI), National Institutes for Health (NIH), or other non-VA resources like professional societies or private sector organizations as potential sources for guideline information, protocols, toolkits, and other topic-specific or skill-specific guidance. These informants described wanting evidence to support their work:

“IHI, NIH, and some of the things that are out there that already have synthesized the evidence-based practice and kind of put it all together. I mean you can do a big lit search and that kind of stuff, but if it’s already put together and it’s already proven and it has like toolkits and those kind of things… [these groups] would synthesize the data, they would look at best practices, then they would develop a toolkit and they would give you all of that”.

## Considerations and Strategies for Working with Hard-to-Engage Sites

“I give you a whole bunch of N-of-1s, but there’s a lot of experience there”

Hard-to-engage sites were described both in the interviews and systematic review findings. We drew from the QUERI spread project papers and interviews, as well as from the 18 publications we identified as either providing descriptions of hard-to-engage sites (n=11) or additionally providing descriptions of strategies used with these hard-to-engage sites after identifying/describing them (n=7).

Generally speaking, hard-to-engage sites had issues meeting the preconditions for scale-up, as described in an earlier section. Common challenges are described below, but the preconditions may not be met for a number of reasons, and interviewees and publications alike supported the highly context-specific nature of challenges faced by hard-to-engage sites, whose “problems vary tremendously” with a “myriad of individual reasons.” The phrase “N-of-1” was used repeatedly throughout the interviews to describe experiences working with hard-to-engage sites.

Similar to the distribution of the Diffusion of Innovation curve,^36^ the proportion of hard-to-engage sites was described as small, with one interviewee directly acknowledging that their spread effort followed “a classic diffusion curve.” Other descriptions were comparable, with proportions of hard-to-engage described as “only a handful” and “up to about 80 to 90 percent adoption went very smoothly,” with the final 10 to 20 percent as hard-to-engage.

While descriptions of hard-to-engage sites often portrayed challenges, a number of beneficial characteristics also warrant mention due to their repeated appearance. The image of the hard-to-engage site is nuanced, and Figure 7 highlights quotes from the interviews that supported the themes that emerged from both literature and interview sources. While these sites may not become early adopters, a better understanding of the variety of hard-to-engage sites may help with tailoring strategies and approaches, rather than treating all hard-to-engage sites the same. What follows is more discussion of these themes.

Figure 7 Hard-to-engage Site Characteristics

### Common Challenges for Spreading to Hard-to-engage Sites

Certain challenges, summarized in the figure above, that sites themselves and/or spread initiators may face when working with hard-to-engage sites are described in greater detail below.

Limited bandwidth or resources to devote to engaging with a particular spread effort was mentioned in nearly every source for this section. Turnover, lack of funding or implementation as an added duty without additional compensation,^59^ and burnout were common in hard-to-engage sites. In one typical description, an effort within VA found that “sites often encountered resource shortages… lack of administrative support, time constraints, [and] departure of key team members.”^60^ No system or model of spread seemed to be immune, as “lack of resources” was frequently mentioned as a factor impeding spread in a non-VA spread effort that was national in scope as well.^49^ Because of a lack of resources or reliance on volunteer effort, potential site personnel would often feel like they “can’t take one more thing” on top of their existing responsibilities, which would often lead to burnout as well.

Local innovations or homegrown solutions to the same problem can present competition that impedes spread, since “there was no expressed need for the program.”^61^ Because their needs are already met locally, “sites with pre-existing [programs] tended to move more slowly to adopt.”^49^ This group can look more like innovators than late adopters in the Diffusions of Innovations model,^36^ as one interviewee noted:

“It doesn’t mean they were low quality sites, though, but that they’re just last sites to adopt. In some ways they were often high-quality, forward-thinking sites that had already tried to solve the solution… they were laggards in terms of adopting [our practice].”

Competing priorities were another challenge for spread efforts, with potential spread sites often very busy addressing local priorities that may not overlap with the aims of a particular spread initiative. “Low implementation facilities were struggling to respond to other higher priority initiatives,”^61^ and “sites often encountered resource shortages because of competing organizational initiatives and a lack of prioritization… at the level of the executive suite.”^60^ While some sites may be low performing sites “in extremis” that are “falling apart… they’re concerned with getting through the day,” the opposite can be true as well: “some of the [hard-to-engage sites] that are otherwise big academic places… they’re focused on something for themselves.”

### Potential Benefits of Working with Hard-to-engage Sites

“Many sites are difficult. I don’t think that makes them bad sites”

In juxtaposition with the challenges, spread initiators raised several ways that they viewed hard-to-engage sites as benefitting their projects, or that the eventual implementation, while slower to start, reaped unique benefits for the sites themselves.

Healthy skepticism was described by interviewees in situations where sites or people initially displayed skepticism, but that this led to collaboration and, in some cases, improvement of the practice or initiative being spread. Rather than being skeptical and slowing spread with malintent, spread initiators distinguished slow-for-slow sake from this group with healthy skepticism, saying they are seeking to understand and appraise the added value of any proposed change: “they are activated and I think in it to win it for their patients.” This initial skepticism is actually a form of engagement, but may be categorized by spread initiators as hard-to-engage if initiators do not continue the conversation. Rather than framing skepticism as opposition, “it can be a way to engage a site by letting them in on what you find and getting their perspectives on what might help”.

Taking the long view was another way to view the potential benefits of working with hard-to-engage sites, as some spread initiators noted that early adoption could lead to superficial engagement and, consequently, abandonment. Conversely, hard-to-engage sites can be signaling that once they are engaged, their hard-won adoption could lead to more sustainable successes in the long-term. One description captured this sentiment well:^59^

“the region that decided to postpone implementation benefitted from the experience of the other regions in working out issues… [they] joined the monthly conference calls and asked many clarifying questions regarding the issues being discussed… [this region] waited and then built a strong base of support for the program… chose to take time to build organizational readiness… when they implemented the program…they were successful”.

Additionally, a late start can proffer other benefits to adopters: “the advantage of later joiners… was that they could draw on and gain support from the experience of early enrollees.”^62^

Alignment with needs between what a spread effort offers and local priorities can be a boon for low performing sites. This underscores the distinction between hard-to-engage sites like late adopters and low performers. These 2 groups may or may not always overlap, and the interviews with spread leads provided a balanced perspective regarding how low performing sites can be easier to work with in regards to aligned priorities:

“there are some [low performers] who want to hide their low-performance status and there are others who want to really get better and take advantage of a learning community and work on it and improve.”

There are some late adopter, low performer sites similar to popular conceptions: “they close themselves off from the outside world because they know they’re not doing well and they can’t take on” a new project. But because a spread effort has so much to offer in addressing a priority need and perceived benefits, this is a group where the strategy or approach to engagement can make a difference in framing the issues as compatibility with existing priorities and support, rather than a punitive situation.

### Useful Strategies for Hard-to-engage Sites

Here we define useful strategies for hard-to-engage sites mapped to hard-to-engage characteristics as shown in Figure 8. The interviews with QUERI project leads and their corresponding publications provided valuable insights for this topic, as most publications did not provide any specific strategies for hard-to-engage sites, and those that did spent no more than a few sentences at most discussing the topic. Thus, the following section is a synthesis of the 7 publications discussing spread strategies for hard-to-engage sites and the QUERI interviews.

Since hard-to-engage sites are highly variable in their needs, QUERI interviewees recommended “a flexible, tailored approach to one [site] at a time,” with another saying, “There’s not just one strategy, but I do think it is a bundle of strategies and some probably work better than others depending on the situation.” The following list (Figure 8) is not exhaustive of all strategies mentioned, but rather highlights the most salient themes from the literature and interviews in how to tailor approaches based on the characteristics described in the last section. To draw linkages between characteristics and strategies, we relied on the descriptions in interviews and literature of both the hard-to-engage sites and the strategies used for those sites.

Figure 8 Strategies Addressing Hard-to-engage Site Needs

### Strategies Used to Address Common Challenges

Spread initiators described a variety of approaches tailored to hard-to-engage sites that faced common challenges. While these linkages between site challenges and strategies do not imply that these are the only strategies that would be helpful in working with hard-to-engage sites, these serve as examples of successful strategies used by spread initiators.

External facilitation is a “multi-faceted process of enabling and supporting individuals, groups and organizations in their efforts to adopt and incorporate clinical innovations into routine practices,”^38^ which includes “interactive problem solving and support.”^39^ The strategy of providing additional supports to those sites with low bandwidth, or who may need extra support for other reasons, was described repeatedly, as in a publication where “iterative quality improvement processes were supported by… the national team”,^49^ where the national team refers to a team of researchers and support staff dedicated to the scale-up of the program. External facilitation often included phone calls where spread initiators helped with “troubleshooting to make sure that things were moving forward.”

QUERI interviewees describe “the sites have said just having regular calls was critical to them just kind of keeping one foot in front of the other,” with sites showing gratitude for the external facilitation: “Thank you for giving me the space. Even though it was squeezed in the margins, you were willing to spend a half-hour call at the end of my day.”

Creating a “web of support,” or working with multiple local people, reduces the burden on any individual and strengthens overall linkages to that site for a spread initiative: “you kind of have to create a web of support around trying to work these things through. So it’s never good to have a single person be your point person in many of these places.” By fostering connections with multiple site contacts, “other team members were able to step in and … they got to know us and [they] were comfortable talking with us as much as the team leaders.” Because that QUERI interviewee, who was the project lead, and their team “did go on site for the big kickoff,” they were able to meet additional site contacts and start relationship-building. This included frontline staff who were to be involved in the work, as well as middle management and even site leadership. The web of support created a redundancy so that if, for instance, a nurse champion was moved out of the initiative, other potential nurse champions were already known to the QUERI team.

Peer to peer communication is important for spread generally, but especially key for sites where local champions are very engaged with the topic and likely have expertise in the area. While this could apply to innovator sites, it also applies to hard-to-engage sites that have homegrown solutions, or who are skeptical about the innovation. This peer to peer communication can be used in a few different scenarios that were highlighted in the literature and interviews. Initially during the buy-in or introductory period, innovations “benefited from champions in each respective practice and specialty to ensure that buy-in was achieved in all facets of the organization.”^63^ Peers with influence may have personal relationships or credibility off which a spread effort can capitalize, as one QUERI interviewee noted:

“it may have given her many contacts throughout the field at local facilities as she worked for several years prior to joining us… thus giving us both our entrée into sites which facilitated and giving us, shall we say, a better contextual knowledge to customize our interventions to the needs of the sites… her credibility in the field was an exceptional part here”.

The peer to peer communication can also be a powerful tool during implementation, with sites working together to learn from one another: “The best part of it is really when teams talk to each other.”

“they kind of stole from each other, which was great”

A variation on this theme included “a system where they had the high-performing sites working with the low-performing sites… to communicate directly with each other. And I think that was really helpful to people.” However, another QUERI interviewee warned that power dynamics needed to be carefully considered: “let me emphasize the words ‘peer-to-peer,’ they have to be on the same exact level and view those people as peers.”

Trialability,^36^ or letting them “kick the tires,” gives local innovators a chance to test against local innovations and can improve the innovation in the process. Spread initiators recommended highlighting the exploratory nature of trying out the innovation: “and if you don’t like it, you can walk away.” One spread initiator had a consistent pitch he used throughout his effort when approaching new sites:

“It’s not perfect, but let’s walk you through it. Here’s how to use it. Hopefully it’s pretty straightforward. Give me any feedback you have… so what we’re asking you to do is take it, use it, either on test cases, just practice with it, or start to deploy it in real reporting. But kick the tires”.

In this case the spread initiator was also a peer to the contacts at the spread sites, which amplified his message by combining the trialability with peer to peer communication. His introduction went on to describe how the innovation was “being used by and for clinicians who developed it.”

Another key to having this strategy be effective is to incorporate feedback received from the spread sites, thereby closing the loop between sites and spread initiators:

“over many years [the team had] a mechanism of feedback from the field, from the users… we had a workgroup of peers for the community… and we rotated them, by the way, every couple years so that lots of people could get experience across the system in this… these small iterative version of the changes that would then get implemented nationally”.

Tackling upstream issues can give a local team an early win related to local priorities, while simultaneously solving issues slowing adoption. Sometimes it is building competencies: “some units didn’t know how to download … a mailing list with labels … so we had to help them work through how to be able to do those types of activities.” Other times it may be building local relationships: “some places had some issues … getting their [IT] to work with them.” For other sites that may “not have as much of a quality improvement or system redesign infrastructure” that was needed for an innovation’s implementation, spread initiators described working on these competencies first. As one QUERI interviewee described, this is particularly important for sites with competing priorities:

“we’re trying to help them navigate through all their other stuff. And they are making an effort… So among all their other activities and other requirements, we’re trying to help them participate and do the work.”

“we’ll go fight the battles for you’

Increasing visibility with multiple levels of leadership, such as engaging the regional leadership, national program offices or policy makers, and local leadership, can help protect the initiative and demonstrate success for those sites involved. As one publication described: “having the involvement of multiple levels of leadership creates a snowball effect throughout an organization and is a significant contributor to Measure Up/Pressure Down’s success”^63^ QUERI interviewees helped build this visibility by giving materials to “our clinical champions to share with their leadership to show that look at the good work we’re doing” and by ensuring that those materials are aligned with the leaders’ interests, the sites have “gotten great direct feedback from the administration.” By also including from the national leadership “a letter congratulating the local team for taking this work on and kudos to them for putting the effort in,” this spread initiator found many ways to connect multiple levels of leadership. Other QUERI interviewees described having national leadership representation as “part of a very engaged executive steering committee, and so we would be feeding results back to them on quite a regular basis.” One QUERI interviewee summed this strategy up as:

“We also give them a voice with leadership above…so I think what we’re kind of referring to as the multilevel stakeholder engagement piece becomes really important, and then having a communications plan from the local folks on up to the [regional] level and up to the medical center level, and in some cases all the way up to [national] levels, becomes really important.”

### Strategies Used to Maximize Potential Benefits

In working with hard-to-engage sites that demonstrated the potential benefits these sites offer during implementation, spread initiators described using a few strategies that maximized engagement and, in turn, potential benefits.

Many spread initiators described using the “hard core and a soft periphery”^64^ model of intervention where the core model is adaptable to local context. This is helpful to get local compatibility and fit with needs that may be different from innovator sites where the intervention was originally tested. In this way a “core provides a standardized method… the soft periphery…adapted by organizations in different ways to maximize fit in the local context and to build acceptability among staff”.^62^

“It’s not one size fits all. They have room to adapt.”

Nearly every QUERI interviewee described using this type of approach, although using different terminology or theoretical support: “we called it a multipronged intervention, but everyone didn’t do the same thing” and another where there was “a small bit of customization, but all the core” pieces were standardized. The final example described a theoretical approach to intervention development with this strategy as a central tenant:

“this whole sort of Evidence-Based Quality Improvement approach is to be responsive to the time and the situation… it was really designed to get a lot of input both at the [regional] level and at the site level in how to adapt or tailor. And it sort of started with an agreement that the ultimate models at the sites would reflect the key elements of the literature in areas that the literature addressed, but that outside of those kind of pillars, the project model would be shaped by the sites themselves.”

Maintaining engagement with sites that are involved in spread activities but not yet adopters, even for prolonged periods of time, gives opportunities for slower adopters to build commitment and find avenues to adoption within their local contexts. In some cases, addressing the concerns of those with negative views by incorporating discussions of their concerns “built up a community of people who could further advocate for the use of the vaccine”^65^ among former skeptics. Other times it may be as simple as allowing non-adopters to continue to participate: when “the region that did not initially start the [program] with other regions… [had a] regional representative joined the study’s monthly conference calls,”^59^ this region later became an adopter.

Framing the message when talking to potential adopter sites is a key consideration, and with hard-to-engage sites, QUERI interviewees described a few approaches that they found to be helpful. In-person initial visits, when possible, had the added benefit of building the “web of support” as described above. QUERI interviewees consistently described focusing on being seen as helpful, rather than punitive or authoritarian – as one interviewee lamented: “I get the sense often that people feel blamed for their problems rather than being made to feel part of the solution.” Another agreed, saying authoritarian styles of engagement “always come across as punishment.” This was counter to what interviewees believed worked well, which included using local baseline data and tying to local priorities in a customized way, as well as using shared learning approaches or an “education focus … [which] resulted in relationships” being built. These all align with the peer to peer communication strategy above as well, by building collaborative relationships:

“somebody there locally recognizes, hey, wait a minute, this might be something that could actually help us. So it’s a little bit of social marketing. And whether you can do that, again, with numbers, definitely trying to communicate to the administration what your intentions are because they get very—nobody wants to be pointed out again that they’re not doing well. So then you actually might be able there to help”.