# Methods

To fully address our objective, we used both systematic review and semi-structured interview methods to collect relevant data, and synthesized these data through qualitative analysis. Below we describe our process, first developing our approach with our stakeholders, then conducting a systematic review and interviews, and finally integrating themes and findings into a cohesive narrative.

## Topic Development

After discussions with the Technical Expert Panel (TEP) and operational partners, the scope of work was expanded from performing a systematic review to include semi-structured interviews with key informants, given the likely paucity of literature directly addressing the objective of this project: to understand strategies available to scale up and spread clinical and administrative practices across large healthcare systems such as the VHA, with a focus on “hard-to-engage” sites, which could also include low performers. This objective has been refined to 2 key areas of inquiry, described below:

1. What does large magnitude spread look like?
  As the QUERI pipeline^35^ and IHI Phases of Scale-up suggest,^1^ large magnitude spread is a planned and organized effort. As there are different forms that this organization or infrastructure can take, the planning process would involve a consideration of certain factors that may be site-specific. Here we sought to define the process of large magnitude scale-up and spread with consideration of hard-to-engage sites, what forms the large magnitude scale-up and spread can take, what should be considered prior to engaging in large magnitude scale-up, and what preconditions and existing networks for spread look like in the VA.
2. Considerations and strategies for working with hard-to-engage sites
  We looked at the commonalities or characteristics of hard-to-engage sites. We defined these in relation to whether the characteristics might have potential benefits in the spread process, or if they cause challenges. We then explored the various strategies that have been used with hard-to-engage sites, since working with hard-to-engage sites as part of a larger spread effort may require tailored approaches.

The review was registered in PROSPERO: CRD42018093380

## Search Strategy

To identify relevant literature, we used 3 topical searches with key terms related to scaling or spread of health interventions, improving low-performing organizations, and learning health system(s). We also searched for similar articles for 5 key publications.^20,34,40–42^ Our searches included the following databases: PubMed, WorldCat, Web of Science, Business Source Complete, and ROCS. See Appendix A for complete search strategy.

In addition to searching these databases, we searched abstracts within a database of all projects funded by the VA QUERI program from fiscal years (FY) 2008–2012. All potentially relevant projects were then collated, and the project leads were identified as potential key informants (described below). In addition, our team then accessed the VA Assessment and Research Reporting Tool, a national database program that supports administrative processes and reporting capabilities for a variety of VA research data, to find any publications affiliated with these projects. These publications were included in all screening and abstraction procedures.

## Study Selection

Three team members independently screened the titles of retrieved citations (IML, DD, PMS). For citations deemed relevant by at least one person, abstracts were then screened independently in duplicate by the same 3 team members. All disagreements were reconciled through group discussion. Full-text review was conducted in duplicate by 2 independent team members (IML, SM), with any disagreements resolved through discussion. Studies were excluded at either the abstract or the full text level if they were: not about a healthcare delivery system (eg, spread within schools or community-based non-profits), about low-income country settings, about learning healthcare systems but not spread (eg only discussed data infrastructure), discussed spread conceptually without data or a specific example or case study, or studies that did not have a large magnitude of spread (fewer than 10 sites included in the spread effort). Studies in low-income countries were viewed as having infrastructure differences too distinct to draw parallels to a VA setting, since these studies often described efforts by international groups coming from foreign countries or working in systems with very different resource or system constraints. Studies with fewer than 10 spread sites were not describing the stage of large magnitude scale-up or spread that this report is focused on, and were typically much more indicative of testing scale-up or regional roll-out projects, as described by the IHI and QUERI frameworks.

## Data Abstraction

For each included publication we abstracted data on the following: the macro model the spread followed (collaborative/exchange to support spread of multiple initiatives within a specific topic area, initiative-specific spread, or embedded spread within a system), any specific micro strategies reported as part of the spread effort, the catalyst or rationale for starting the spread effort, focus/topic area of the practice or initiative, the country or countries where spread occurred, if and how the publication described working with hard-to-engage sites, and magnitude of spread. Each publication was subject to dual data abstraction, with any discrepancies resolved through team discussion.

## Quality Assessment

The focus of this review, which is describing scale-up and spread, is not one for which there are existing instruments to assess the quality of studies. With no established criteria for deciding on quality, and because it was beyond the scope of this work to develop such criteria, we did not perform any quality assessment.

## Key Informant Interview Sampling and Data Collection

We used the consolidated criteria for reporting qualitative research (COREQ) to guide our reporting of the qualitative component of this work.^43^ We invited a total of 24 key stakeholders to participate in semi-structured interviews. An email invitation to participate in an interview was sent to each identified individual, and a phone interview was scheduled with those who agreed to participate. The semi-structured interviews were recorded and transcribed. Sample interview guide questions are shown in Appendix B. The average interview duration was 36 minutes and 30 seconds. The interviews were conducted by the MD- or PhD-educated members of the trained qualitative team (IML, ALK, CL), with additional team members in attendance as possible. All 3 interviewers are female researchers who are familiar with implementation science and quality improvement topics. In most cases participants and interviewers were not familiar with one another, the exception being during the pilot interview. The participants were drawn from 2 distinct samples, described below.

### QUERI Project Leads

We identified 39 projects in the database of QUERI proposals that described scale or spread activities in their abstracts. Of these, 11 projects described conducting national, multi-regional, or multi-site spread as part of the scope of the project. An additional 14 projects described evaluations of national policy or program spread efforts, with the final 10 projects describing analyses or work with low performing sites. We selected the 2 national spread projects, 2 additional multi-site/multi-region projects, 3 evaluation projects, and one analysis of low performing sites. We chose the projects based on their size and any specific references to spread activities being analyzed or implemented. Contacts from all 8 of the projects agreed to be interviewed, and they shared their perspectives on and experiences with strategies to scale up and spread clinical and administrative practices across healthcare systems, with a focus on “hard to reach” sites, which could also include low performers. In one case a QUERI project lead did not respond to our contact, so we interviewed a different co-investigator from the same project instead.

### SAIL Improvers

The VA uses a performance metric system called Strategic Analytics for Improvement and Learning (SAIL),^44^ an adapted version of the Thomson Reuters Top Health Systems Study, that tracks a multitude of individual metrics and combines them to produce an overall global score for each VA facility which is adjusted for facility complexity. Facilities are sorted into quintiles using this overall score. The perspectives of these sites may reflect how and when sites may engage in spread efforts, and what types of resources these sites used to improve.

We sorted the 146 VA sites with data from all quarters in FY2012 through FY2017. These were categorized into 3 groups: sites whose rank remained in the lower quintiles (quintiles 3 through 5 throughout the reporting period, n=34), sites whose rank remained in the higher quintiles (quintiles 1–3 throughout the reporting period, n=38), and sites that changed ranks (n=75). From this last group, we placed sites in the improver group that had begun with scores in the lower quintiles in the first 3 quarters reported (FY2011 and FY2012) and had made improvements to move up to the top quintiles and had maintained high quintile ranking in the latest fiscal year (n=16). See Appendix C for example data representing these categories. One example for an improver site is site E in the Appendix, which was ranked in the fifth quintile in FY2011, then in the fourth quintile for all 4 quarters in FY2012. In FY2013 site E ranked in the third quintile in quarter one, second quintile in quarters 2 and 3, and first quintile in quarter 4. This first quintile ranking persisted through the rest of the reported fiscal years (FY2017 quarter 4).

We then sampled 7 representative sites from the improver group, based on facility complexity and diversity of location, and invited 2 key informants from each site. Two additional sites were contacted but the original contact did not respond. These key informants represented one person in a leadership position and one person closely involved in SAIL improvement activities at the site, and were identified by TEP members or team members who were familiar with the sites. Once we had contact with a site, our first contact could suggest additional or replacement interviewees if they thought there were other, more appropriate individuals. We invited a total of 20 key stakeholders from these sites with SAIL improvements, of whom 16 shared perspectives on and experiences with strategies their sites used to improve their overall SAIL score, as well any specific metrics that may have been targeted for improvement. Of the 4 invited stakeholders who did not respond, 2 stakeholders were the initial contacts at the nonresponding sites, one stakeholder was unable to participate due to scheduling conflicts, and one individual referred our team to another colleague at the same site, who we interviewed instead.

## Data Synthesis and Analysis

We drew from a combination of both key informant interviews and literature review findings to address the key questions. We first analyzed the literature and interviews separately, as described below, and then synthesized across these data sources by comparing and contrasting findings within sections. Within each results section we describe the sources we drew from for that section.

### Literature Review

Our review is a narrative analysis. We synthesized descriptions of spread efforts from included publications.

### Key Informant Interviews

Drawing primarily on matrix analysis,^45,46^ an inductive and deductive team-based analytical approach was performed. A matrix analysis is a tabular format that collects and arranges data for easy viewing in one place, permits detailed analysis, and sets the stage for later cross-case analysis with other comparable sites.^45,46^ Based on our interview guides, we developed separate templates for QUERI and SAIL interviews to rapidly organize qualitative data by key themes or questions.^47^ Each interview was analyzed by 3 members of the team (IML, DD, SM), and consistency of interpretation was regularly checked through team discussion. See Appendix D for QUERI and SAIL templates used in analysis.

## Peer Review

A draft version of the report was reviewed by technical experts and clinical leadership. Reviewer comments and our response are documented in Appendix E.