# Introduction

The process of moving research insights into clinical practice can be slow and a gap often remains between best practices, frequently developed within single sites or small populations, and general practice delivered at a population scale.^1–17^ The field of implementation science seeks to mend this gap by promoting the adoption and appropriate use of effective interventions, practices, and programs, which includes the study of scale-up and spread of innovations.^18–21^ The terms “scale-up” and “spread” are not well-differentiated and often used together or interchangeably,^19,22^ but the key definitional components repeatedly emphasized are the pre-established effectiveness of the innovation; the expansion across systems, sites, or settings; and the intentional process or active effort involved.^1,19,20,22–28^ An exemplar definition from the World Health Organization, used by the Conference to Advance the Science and Practice of Scale-up and Spread of Effective Health Programs in Healthcare and Public Health,^19^ contains all these elements:^1^

Scale-up/Spread

“Deliberate efforts to increase the impact of innovations successfully tested in pilot or experimental projects so as to benefit more people and to foster policy and program development on a lasting basis.”

Numerous frameworks and models have been developed for scale-up and spread,^1–6,22,29–33^ with a recent review identifying 24 concepts, theories, or models in the public health sector alone.^23^ However, many of these are focused on particular settings or health areas (eg, low- and middle-income countries, maternal nutrition), and may not be directly applicable to more general spread efforts.^19,22,23^ In large healthcare systems such as the VA, organizations are multi-level and require models flexible enough to adapt to this setting, given that work across these systems “requires explicit attention to the interactions between and among multiple levels,” even for innovations targeting only one piece of the larger organization.^34^ For this report, we focus on 2 widely-used frameworks that are general and describe the process of multi-site scale-up and spread: the Institute for Healthcare Improvement’s phases of scale-up^1^ and the QUERI pipeline^35^ (see Figure 1 below). These 2 frameworks follow similar general steps in the spread process: piloting and initial testing of some idea or innovation, then testing scale-up before moving to full scale-up or spread. These frameworks are not without key distinctions. The QUERI framework is focused on moving research evidence to practice, characterizing the process as a “pipeline.”^35^

This pipeline has a core premise that innovations must be “evidence-based,” and describes a top-down process that is then assumed to get that innovation broadly implemented. The IHI framework, on the other hand, is focused on grassroots process improvement, and the basis for cultivating an innovation to be spread or scaled up is not necessarily a strong evidence base.^1^ Rather, local demonstration of improvement is necessary, through piloting and initial testing as the framework depicts, before scaling up and/or spreading more broadly. While there is a fundamental difference between the evidence-based approach and the grassroots process improvement approach, the similarities in the later stages of these frameworks is the key factor we wanted to emphasize in this report, so we chose to draw from both frameworks to highlight the ways in which they align.

Both frameworks differentiate between 3 phases. In both cases the third phase, “go to full-scale” or “national roll-out effort,” describes an effort that includes many organizations. This last phase is depicted as a homogenous process in these frameworks, but often captures a heterogeneous group of organizations and settings. One theory that would suggest that this is not a homogenous group is the Diffusion of Innovations theory, which proposes that adoption of any innovation fits a curved pattern when spreading across a large population, with different groups of adopting individuals or organizations fitting into 5 sequential groups with different adopting habits and characteristics.^36^ Innovators and early adopters are seen as more risk-taking and engage more quickly with new innovations. The early and late majority groups tend to observe the actions of these earlier groups before making their adoption choices, and the late adopters are characterized as having the greatest skepticism for change and last to adopt. These descriptions fit with spread activities in the frameworks, where innovators would conduct initial piloting and testing and early adopters would then be the next group to engage with during initial spread efforts. However, while spread frameworks tend to group the rest of the spread process into one category, this is discordant with how Diffusion of Innovation describes the 3 remaining groups, which have unique characteristics. The IHI and QUERI frameworks are not unique in that late and non-adopters are typically not the focus of work published in this area.^37^

As a note, Diffusion of Innovations theory is not perfect in its application to the scale-up and spread process, with observations of individuals rather than organizations as its basis and other issues related to characterizations of those individuals,^36,38^ but other work in this area does suggest that adopter characteristics do vary at an organizational level.^39^ Given the specific characteristics Rogers ascribed to late adopters, or laggards as he called them,^37^ we will be using the term hard-to-engage as a generic term to describe the group of organizations that scale-up and spread efforts have struggled to reach. There is a lack of information about how to tailor approaches to these hard-to-engage sites in scale-up and spread efforts.

Figure 1 Adopter Groups and Spread Process

*Diffusion of Innovations curve,^36^ IHI Phases of scale-up,^1^ and QUERI pipeline^35^

Going to full scale or completing large magnitude spread requires more than ad hoc connections, and the coordinated effort can be thought of as a macro model driving the infrastructure or organization of a spread effort. Spread initiators may need to tailor their model or apply unique strategies to reach hard-to-engage sites, especially in large magnitude spread efforts where the initial model for going full scale may reach most sites, but not all. Additional, or different, approaches may be required to engage the hard-to-engage sites. For instance, collaboratives that rely on voluntary participation and activated users to engage with the effort may not have strategies or local champions in place to reach sites that do not reach out to join the network themselves.

The objective of this project is to understand strategies available to scale up and spread clinical and administrative practices across large healthcare systems such as the VHA, with a focus on “hard-to-engage” sites.