# APPENDIX F Citations for Excluded Studies

## Learning health system but not spread (n=62)

1 Errata to: Creating a rapid-learning health system, 2007–13 [Health Affairs, 33, 9 (2014), 1703]. Health Affairs. 2014;33(9):1703a.25201681
2 JASON Report Urges Learning Health System. Journal of AHIMA. 2015;86(2).
3 Brooks D, Douglas M, Aggarwal N, Prabhakaran S, Holden K, Mack D. Developing a framework for integrating health equity into the learning health system. Learn Health Sys. 2017;1:e10029. 10.1002/lrh2.10029. [Internet Resource; Article; Computer File]. 2017; 1 online resource. Available at: https://nls.ldls.org.uk/welcome.html?ark:/81055/vdc_100052795475.0x000001
4 Abernethy AP. Demonstrating the learning health system through practical use cases. Pediatrics. 2014;134(1):171–172.24935998
5 Anderson GM. Moving from a Learning-Disabled to a Rapid-Learning Healthcare System: Good Governance for Innovation. HealthcarePapers. 2016;15(3):4–7.
6 Andersson AC. Managers’ Views and Experiences of a Large-Scale County Council Improvement Program: Limitations and Opportunities. Qual Manag Health Care. 2013;22(2):152–160.23542370
7 Angus DC. Fusing randomized trials with big data: The key to self-learning health care systems? JAMA - Journal of the American Medical Association. 2015;314(8):767–768.26305643
8 Aubry WM. Ways decision makers can use evidence to improve patient outcomes in learning health systems: a message from the guest editor. EGEMS (Washington, DC). 2013;1(2):1050.
9 Barba P, Burns L, Litzow M, . Success of an international learning healthcare system in hematopoietic cell transplantation: The American society of blood and marrow transplantation clinical case forum. Bone Marrow Transplantation. 2016;51 SUPPL. 1:S553.26999543
10 Bellack JP, Thibault GE. Creating a Continuously Learning Health System Through Technology: A Call to Action. The Journal of nursing education. 2016;55(1):3–5.26812374
11 Delaney BC, Curcin V, Andreasson A, . Translational Medicine and Patient Safety in Europe: TRANSFoRm--Architecture for the Learning Health System in Europe. BioMed research international. 2015;2015:961526.26539547
12 Edwards N. Can quality improvement be used to change the wider healthcare system? Quality & safety in health care. 2005;14(2):75–75.15805447
13 Essen A, Lindblad S. Innovation as emergence in healthcare: unpacking change from within. Social science & medicine (1982). 2013;93:203–211.23021848
14 Fagnan LJ, Dolor RJ. PBRNS discuss utilizing big data for research and within a learning health system. Annals of family medicine. 2015;13(2):185.25755043
15 Fahey KR. The Pioneering Role of the Vaccine Safety Datalink Project (VSD) to Advance Collaborative Research and Distributed Data Networks. EGEMS (Washington, DC). 2015;3(1):1195.
16 Farrokhi EDEE, degree s. Building a learning healthcare network: the transition of the Vascular Interventional Surgical Care Outcomes Assessment Program to the Comparative Effectiveness Research Translation Network (VI SCOAP to CERTAIN). In: 2013: http://hdl.handle.net/1773/23769.
17 Finney Rutten LJ, Alexander A, Embi PJ, . Patient-Centered Network of Learning Health Systems: Developing a resource for clinical translational research. Journal of clinical and translational science. 2017;1(1):40–44.28515960
18 Friedman C, Sullivan K. Introduction to the learning health systems, big data, and socio-technical change minitrack. 2015;2015–March:3104.
19 Grumbach K, Lucey CR, Johnston SC. Transforming from centers of learning to learning health systems: the challenge for academic health centers. Jama. 2014;311(11):1109–1110.24643597
20 Harrington RA. Appropriate Use Criteria for Coronary Revascularization and the Learning Health System: A Good Start. Jama. 2015;314(19):2029–2031.26550932
21 Huvane K. Linking the chain. Sisters of Mercy’s highly successful supply chain is becoming a best practice in the healthcare industry. Healthcare informatics: the business magazine for information and communication systems. 2008;25(9):32–35.
22 Kalra A, Adusumalli S, Sinha SS. Cultivating Skills for Success in Learning Health Systems: Learning to Lead. Journal of the American College of Cardiology. 2017;70(19):2450–2454.29096813
23 Kelley M, James C, Alessi Kraft S, . The Role of Patient Perspectives in Clinical Research Ethics and Policy: Response to Open Peer Commentaries on “Patient Perspectives on the Learning Health System”. The American journal of bioethics: AJOB. 2016;16(2):W7–9.
24 Kikaya H. Health systems science can learn from medicine’s evidence revolution. South African medical journal = Suid-Afrikaanse tydskrif vir geneeskunde. 2014;104(7):454.25298983
25 Klein WM. Conducting multilevel intervention research: leveraging and looking beyond methodological advances. Journal of the National Cancer Institute Monographs. 2012;2012(44):78–79.22623599
26 Krumholz HM, Terry SF, Waldstreicher J. Data Acquisition, Curation, and Use for a Continuously Learning Health System. Jama. 2016;316(16):1669–1670.27668668
27 Kuchinke WOC, Verheij RA, Veen EBv, Delaney BC. Development Towards a Learning Health System - Experiences with the Privacy Protection Model of the TRANSFoRm Project. Data protection on the move: current developments in ICT and privacy/data protection, Page. 2016;9789401773751(NL-LeOCL):931544158.
28 Levy AE, Ho PM. Nonadherence in the Learning Healthcare System: Avoiding a Mountain by Seeing the Bumps. Circulation Cardiovascular quality and outcomes. 2017;10(10).
29 McElwee NE, Dubois RW. From methods to policy: Enthusiasm for rapid-learning health systems exceeds the current standards for conducting it. Journal of comparative effectiveness research. 2013;2(5):425–427.24236738
30 McNolty LA, Payne R. Relying on Trust for Research on Medical Practice in Learning Health Systems. The American journal of bioethics: AJOB. 2015;15(9):30–32.
31 Mistry KB, Forrest CB. Applying Evidence From Clinical Trials: Need for Pediatric Learning Health System Research. Pediatrics. 2017;140(6).
32 Moser A, van der Weijden T, Steckelberg A. Patient participation - What is it? Zeitschrift fur Evidenz, Fortbildung und Qualitat im Gesundheitswesen. 2016;110–111:12–15.
33 Myers SR, Carr BG, Branas CC. Uniting Big Health Data for a National Learning Health System in the United States. JAMA pediatrics. 2016;170(12):1133–1134.27723889
34 Nahm ES. Mental Health Nurses: Are We Ready for a “Learning Health System”? Journal of the American Psychiatric Nurses Association. 2015;21(4):284–286.26282673
35 Park K, Park MD, Longhurst CA. Patient and Family Access to Electronic Health Records: A Key Ingredient for a Pediatric Learning Health System. Journal of participatory medicine. 2015;7.
36 Patel K, Abernethy AP. Rapid learning systems. In: Oncologic Emergency Medicine: Principles and Practice. Springer International Publishing; 2016:79–93.
37 Penley WC. ASCO demonstrates prototype for CancerLinQ[TM]: new ‘Learning Health System’ will transform cancer care. ASCO Connection. 2013;4(4).
38 Pontin D, Temple M. The case for using an evolutionary professional protocol for improving care: act local, think global. The journal of the Royal College of Physicians of Edinburgh. 2017;47(1):10–12.28569276
39 Psek WA, Stametz RA, Bailey-Davis LD, . Operationalizing the learning health care system in an integrated delivery system. EGEMS (Washington, DC). 2015;3(1):1122.
40 Raths D. Early Building Blocks of the Learning Health System Falling into Place. Healthcare Informatics. 2015;32(1).
41 Roberts DW. Improving care and practice through learning health systems. Nursing management. 2013;44(4):19–22.
42 Rubin JC, Friedman CP. Weaving together a healthcare improvement tapestry. Learning health system brings together health data stakeholders to share knowledge and improve health. Journal of AHIMA. 2014;85(5):38–43.
43 Seid M, Margolis PA, Opipari-Arrigan L. Engagement, peer production, and the learning healthcare system. JAMA pediatrics. 2014;168(3):201–202.24446048
44 Selby J,. Larson EB,. Kaushal R,. Zirkle M,. Lopez MH,. Accelerating medical evidence generation and use: summary of a meeting series. Washington, DC: National Academy of Medicine; 2017.
45 Sheppard DN. EuroCareCF: working together to improve patient care and therapy development. Journal of cystic fibrosis: official journal of the European Cystic Fibrosis Society. 2011;10: Suppl 2:S1–4.21658628
46 Smoyer WE, Embi PJ, Moffatt-Bruce S. Creating Local Learning Health Systems. JAMA: Journal of the American Medical Association. 2016;12(20):23.
47 Starren JB, Winter AQ, Lloyd-Jones DM. Enabling a Learning Health System through a Unified Enterprise Data Warehouse: The Experience of the Northwestern University Clinical and Translational Sciences (NUCATS) Institute. Clinical and translational science. 2015;8(4):269–271.26032246
48 Stevenson RD. Integration of research and clinical practice: the future is now. Developmental Medicine and Child Neurology. 2017;59(2):119–120.27634036
49 Stoto MA. New analytical methods for a learning healthcare system: a message from the guest editor. EGEMS (Washington, DC). 2013;1(3):1055.
50 Stucki G, Bickenbach J. The Implementation Challenge and the Learning Health System for SCI Initiative. American journal of physical medicine & rehabilitation. 2017;96(2 Suppl 1):S55–s60.28059879
51 Stucki G, Bickenbach J. The International Spinal Cord Injury Survey and the Learning Health System for Spinal Cord Injury. American journal of physical medicine & rehabilitation. 2017;96(2 Suppl 1):S2–s4.28059873
52 Sullivan K, Ben-Ari AY, Horan T, Chismar W. Introduction to Learning Health Systems Minitrack. 2016;2016–March:3297.
53 Sullivan T. Improving quality and performance in Ontario’s cancer services: lessons for constructing a learning healthcare system. Healthcare quarterly (Toronto, Ont). 2015;17 Spec No:5–9.
54 Tavazzi L. Observational research as a platform for evidence-based public health policies and learning health systems. European heart journal. 2017;38(24):1891–1894.28379426
55 Tcheng JE,. Optimizing strategies for clinical decision support: summary of a meeting series. Washington, DC: National Academy of Medicine; 2017.
56 Tepas JJ, 3rd. Injury prevention in a self-learning health system. The journal of trauma and acute care surgery. 2015;79(3 Suppl 1):S1.26308115
57 Weinberg M. Developing a learning healthcare system. American Journal of Pharmacy Benefits. 2012;4(2):78–79.
58 Yoder-Wise PS. The Continuously Learning Health System: Recommendations From the Josiah Macy Jr. Foundation. Journal of continuing education in nursing. 2015;46(9):379–380.26352036
59 Young PJ. Learning Healthcare Systems Will Protect Patients from Unscientific Practice Variation. Annals of the American Thoracic Society. 2017.
60 Yu PP. Perspectives on the Implementation of an Ethical Rapid Learning Health System. Journal of oncology practice. 2017;13(3):151–153.28118109
61 Yu PP, Hoffman MA, Hayes DF. Biomarkers and oncology: the path forward to a learning health system. Archives of pathology & laboratory medicine. 2015;139(4):451–456.25152310
62 Zalon ML. Technology and Continuously Learning Health Systems. Journal of continuing education in nursing. 2016;47(6):243–245.27232218

## Discussion of spread (n=45)

1 Bailey JE. EHR initiatives in the Mid-South. Tennessee medicine: journal of the Tennessee Medical Association. 2008;101(7):27–28.
2 Bindman AB. A Shared Responsibility for Developing a Learning Health System. Journal of nursing care quality. 2017;32(2):95–98.28225531
3 Budrionis A, Bellika JG. The Learning Healthcare System: Where are we now? A systematic review. Journal of biomedical informatics. 2016;64:87–92.27693565
4 Campion TR, Jr., Gadd CS. Peers, regulators, and professions: the influence of organizations in intensive insulin therapy adoption. Quality management in health care. 2009;18(2):115–119.19369854
5 Chantler T, Lwembe S, Saliba V, . “It’s a complex mesh”- how large-scale health system reorganisation affected the delivery of the immunisation programme in England: a qualitative study. BMC health services research. 2016;16:489.27633653
6 Chatwood S, Parkinson A, Johnson R. Circumpolar health collaborations: a description of players and a call for further dialogue. International journal of circumpolar health. 2011;70(5):576–583.22067095
7 Clancy CM, Margolis PA, Miller M. Collaborative networks for both improvement and research. Pediatrics. 2013;131: Suppl 4:S210–214.23729762
8 Clark SR, Wilton L, Baune BT, Procter N, Hustig H. A state-wide quality improvement system utilising nurse-led clinics for clozapine management. Australas Psychiatry. 2014;22(3):254–259.24811715
9 Clay-Williams R, Nosrati H, Cunningham FC, Hillman K, Braithwaite J. Do large-scale hospital- and system-wide interventions improve patient outcomes: a systematic review. BMC health services research. 2014;14:369.25187292
10 Crabtree BF, Nutting PA, Miller WL, . Primary care practice transformation is hard work: insights from a 15-year developmental program of research. Medical care. 2011;49 Suppl:S28–35.20856145
11 Evans T, Nishtar S, Atun R, Etienne C. Scaling up research and learning for health systems: time to act. Lancet. 2008;372(9649):1529–1531.18984175
12 Finnell D. Screening, brief intervention, and referral to treatment (SBIRT): moving from passive spread to widespread adoption. Journal of addictions nursing. 2013;24(3):195–198.24621550
13 Fulop N, Boaden R, Hunter R, . Innovations in major system reconfiguration in England: a study of the effectiveness, acceptability and processes of implementation of 2 models of stroke care. Implementation Science. 2013;8.
14 Greene SM, Reid RJ, Larson EB. Implementing the learning health system: from concept to action. Annals of internal medicine. 2012;157(3):207–210.22868839
15 Greenhalgh T, Wherton J, Papoutsi C, . Beyond Adoption: A New Framework for Theorizing and Evaluating Nonadoption, Abandonment, and Challenges to the Scale-Up, Spread, and Sustainability of Health and Care Technologies. Journal of medical Internet research. 2017;19(11):e367.29092808
16 Hamilton JD. Concluding the series on evidence-based practice: the spread of excellence in child and adolescent psychiatry. Journal of the American Academy of Child and Adolescent Psychiatry. 2008;47(11):1222–1227.18931609
17 Herbert I, de Lusignan S. Further changes are needed if the National Care Record Service (NCRS) implementation is to succeed. Informatics in primary care. 2009;17(3):161–164.
18 Ilott I, Gerrish K, Pownall S, Eltringham S, Booth A. Exploring scale-up, spread, and sustainability: an instrumental case study tracing an innovation to enhance dysphagia care. Implementation science: IS. 2013;8:128.24168667
19 Jacobsen PB. New Challenges in Psycho-Oncology Research II: A health care delivery, dissemination, and implementation research model to promote psychosocial care in routine cancer care. Psycho-oncology. 2017;26(4):419–423.28398012
20 Kolodner R. At the helm. ONCHIT’s chief talks about his plans for spreading the HIT gospel, as well as plans for the organization’s future. Interview by Anthony Guerra. Healthcare informatics: the business magazine for information and communication systems. 2007;24(9):26–28, 30.
21 Korsen N, Pietruszewski P. Translating evidence to practice: 2 stories from the field. Journal of clinical psychology in medical settings. 2009;16(1):47–57.19238525
22 Laycock A, Bailie J, Matthews V, Bailie R. Interactive Dissemination: Engaging Stakeholders in the Use of Aggregated Quality Improvement Data for System-Wide Change in Australian Indigenous Primary Health Care. Front Public Health. 2016;4.
23 Leigh JA, Long PW, Barraclough BH. The clinical support systems program: supporting system-wide improvement. Med J Aust. 2004;180(10):S101–S103.15139847
24 Lewis RQ, Fletcher M. Implementing a national strategy for patient safety: lessons from the National Health Service in England. Quality & safety in health care. 2005;14(2):135–139.15805460
25 Malcarney MB, Horton K, Seiler N, Hastings D. Advancing the Public’s Health by Scaling Innovations in Clinical Quality. Public Health Rep. 2017;132(4):512–517.28595029
26 Mandel KE. Aligning Rewards With Large-Scale Improvement. JAMA-J Am Med Assoc. 2010;303(7):663–664.
27 Mendel P, Siegel S, Leuschner KJ, Gall EM, Weinberg DA, Kahn KL. The national response for preventing healthcare-associated infections: infrastructure development. Medical care. 2014;52(2 Suppl 1):S17–24.
28 Moloney RM, Tambor ES, Tunis SR. Patient and clinician support for the learning healthcare system: recommendations for enhancing value. Journal of comparative effectiveness research. 2016;5(2):123–128.26930026
29 Noseworthy JH. What is ahead for Mayo Clinic? Mayo Clinic proceedings. 2014;89(4):440–443.24684871
30 Patel MR, Jones WS. Peripheral Artery Disease Therapies May Perform Differently in Practice Than in Randomized Trials: The Need for Learning Health Systems. JACC Cardiovascular interventions. 2016;9(7):725–727.27056312
31 Paulsell D, Del Grosso P, Supplee L. Supporting replication and scale-up of evidence-based home visiting programs: assessing the implementation knowledge base. American journal of public health. 2014;104(9):1624–1632.25033117
32 Perla RJ, Bradbury E, Gunther-Murphy C. Large-scale improvement initiatives in healthcare: a scan of the literature. Journal for healthcare quality: official publication of the National Association for Healthcare Quality. 2013;35(1):30–40.
33 Powell BJ, Beidas RS. Advancing Implementation Research and Practice in Behavioral Health Systems. Administration and policy in mental health. 2016;43(6):825–833.27591772
34 Prins M, Bruneau J. Estimates are not enough: scaling-up interventions to improve the health of people who inject drug. Lancet Glob Health. 2017;5(12):E1162–E1163.29132603
35 Pronovost PJ, Berenholtz SM, Needham DM. Translating evidence into practice: a model for large scale knowledge translation. BMJ (Clinical research ed). 2008;337:a1714.
36 Roy DA, Candas B, Litvak E, Boileau L. The necessary - but not sufficient - Leadership of research to transform the health systems. Healthcare Papers. 2016;16:21–25.27734786
37 Rycroft-Malone J, Wilkinson JE, Burton CR, . Implementing health research through academic and clinical partnerships: a realistic evaluation of the Collaborations for Leadership in Applied Health Research and Care (CLAHRC). Implementation science: IS. 2011;6:74.21771329
38 Strite S, Stuart ME. What is an evidence-based, value-based health care system? (Part 1). Physician executive. 2005;31(1):50–54.
39 Waterman H, Boaden R, Burey L, . Facilitating large-scale implementation of evidence based health care: insider accounts from a co-operative inquiry. BMC health services research. 2015;15:60.25889054
40 Westbrook JI, Braithwaite J, Gibson K, . Use of information and communication technologies to support effective work practice innovation in the health sector: a multi-site study. BMC health services research. 2009;9:201.19895703
41 White M, Wells JSG, Butterworth T. The transition of a large-scale quality improvement initiative: a bibliometric analysis of the Productive Ward: Releasing Time to Care Programme. J Clin Nurs. 2014;23(17–18):2414–2423.24646373
42 Wutzke S, Benton M, Verma R. Towards the implementation of large scale innovations in complex health care systems: views of managers and frontline personnel. BMC research notes. 2016;9:327.27352864
43 Yano EM, Green LW, Glanz K, . Implementation and spread of interventions into the multilevel context of routine practice and policy: implications for the cancer care continuum. Journal of the National Cancer Institute Monographs. 2012;2012(44):86–99.22623601
44 Young GJ, Charns MP, Barbour GL. Quality improvement in the US Veterans Health Administration. International journal for quality in health care: journal of the International Society for Quality in Health Care. 1997;9(3):183–188.
45 Zephyrin LC, Katon JG, Yano EM. Strategies for transforming reproductive healthcare delivery in an integrated healthcare system: a national model with system-wide implications. Current opinion in obstetrics & gynecology. 2014;26(6):503–510.25333678

## Small rollout (n=20)

1 Booth BJ, Zwar N, Harris MF. Healthcare improvement as planned system change or complex responsive processes? a longitudinal case study in general practice. BMC family practice. 2013;14.
2 Contandriopoulos D, Brousselle A, Dubois CA, . A process-based framework to guide nurse practitioners integration into primary healthcare teams: results from a logic analysis. BMC health services research. 2015;15:78.25889415
3 Cresswell KM, Worth A, Sheikh A. Comparative case study investigating sociotechnical processes of change in the context of a national electronic health record implementation. Health informatics journal. 2012;18(4):251–270.23257056
4 D’Andreta D, Scarbrough H, Evans S. The enactment of knowledge translation: a study of the Collaborations for Leadership in Applied Health Research and Care initiative within the English National Health Service. Journal of health services research & policy. 2013;18:(3 Suppl):40–52.
5 DiGiorgio K, Anderson WG, Cannesson M, Gleason N, O’Neill-Page E, Ong MK. University of California Center for Health Quality and Innovation: experiences from a system approach to scaling up effective interventions. [Internet Resource; Article]. 2015; http://www.implementationscience.com/content/10/S1/A16
6 Dlugacz YD, Stier L, Lustbader D, Jacobs MC, Hussain E, Greenwood A. Expanding a performance improvement initiative in critical care from hospital to system. The Joint Commission journal on quality improvement. 2002;28(8):419–434.12174407
7 Fulop NJ, Ramsay AIG, Perry C, . Explaining outcomes in major system change: a qualitative study of implementing centralised acute stroke services in 2 large metropolitan regions in England. Implementation Science. 2016;11.
8 Hirsch MD. How a ‘Learning Health System’ Lowered the Cost of Care. 2017.
9 Lamont SS. “See and Treat”: spreading like wildfire? A qualitative study into factors affecting its introduction and spread. Emergency medicine journal: EMJ. 2005;22(8):548–552.16046753
10 Leclerc E, Lavoie-Tremblay M. Implementation of a nursing professional practice model. Healthcare management forum. 2007;20(3):24–29.18372886
11 Mathews S, Golden S, Demski R, Pronovost P, Ishii L. Advancing health care quality and safety through action learning. Leadership in health services (Bradford, England). 2017;30(2):148–158.
12 Morgenthaler TI, Lovely JK, Cima RR, . Using a framework for spread of best practices to implement successful venous thromboembolism prophylaxis throughout a large hospital system. American journal of medical quality: the official journal of the American College of Medical Quality. 2012;27(1):30–38.21835811
13 Radnor Z, Lovell B. Success factors for implementation of the balanced scorecard in a NHS multi-agency setting. International journal of health care quality assurance incorporating Leadership in health services. 2003;16(2–3):99–108.12870249
14 Rosen M, Mueller BU, Milstone AM, . Creating a Pediatric Joint Council to Promote Patient Safety and Quality, Governance, and Accountability Across Johns Hopkins Medicine. Joint Commission Journal on Quality and Patient Safety. 2017;43(5):224–231.28434455
15 Rosenman MB, Decker B, Levy KD, Holmes AM, Pratt VM, Eadon MT. Lessons Learned When Introducing Pharmacogenomic Panel Testing into Clinical Practice. Value in Health. 2017;20(1):54–59.28212969
16 Schuller KA, Kash BA, Gamm LD. Studer Group(R)’s evidence-based leadership initiatives. Journal of health organization and management. 2015;29(6):684–700.26394252
17 Simon TD, Starmer AJ, Conway PH, . Quality improvement research in pediatric hospital medicine and the role of the Pediatric Research in Inpatient Settings (PRIS) network. Academic pediatrics. 2013;13:(6 Suppl):S54–60.24268086
18 Smoyer WE, Embi PJ, Moffatt-Bruce S. Creating Local Learning Health Systems: Think Globally, Act Locally. Jama. 2016;316(23):2481–2482.27997662
19 Tonges M, McCann M, Strickler J. Translating caring theory across the continuum from inpatient to ambulatory care. The Journal of nursing administration. 2014;44(6):326–332.24835143
20 Velanovich V, Rubinfeld I, Patton JH, Jr., Ritz J, Jordan J, Dulchavsky S. Implementation of the National Surgical Quality Improvement Program: critical steps to success for surgeons and hospitals. American journal of medical quality: the official journal of the American College of Medical Quality. 2009;24(6):474–479.19584373

## Full text unavailable (n=22)

1 Grant Furthers Quest for ‘Learning Health System Model’. Journal of AHIMA. 2013;84(4).
2 Abernethy AP. Aahpm scientific research award winner: A learning system to optimize care for people with advanced illness. Journal of Pain and Symptom Management. 2016;51(2):389.
3 Bermel R, Jones S, Izbudak I, . Multicenter MRI standardization to allow quantitative metrics in routine care of multiple sclerosis patients: The Multiple Sclerosis Partners Advancing Technology and Health Solutions (MS PATHS) initiative. Neurology. 2017;88(16):2017–2004.28446651
4 Bermel R, Mowry E, Krupp L, . Multiple sclerosis partners advancing technology and health solutions (MS PATHS): Initial launch experience. Neurology. 2017;88(16):2017–2004.28446651
5 Bingham CA, Pratt J, Yildirim-Toruner C, . Pediatric rheumatology care and outcomes improvement network demonstrates improvement on quality measures for children with juvenile idiopathic arthritis. Arthritis and Rheumatology. 2017;69 Supplement 4:6–7.27696783
6 Carmona JM, Howe E, Zapata R, Stevens D, Murphy JK. The Teen Health Improvement Program: A System-Wide Initiative to Improve the Quality of Care for Adolescents Served by the Country’s Largest Public Hospital System. J Adolesc Health. 2015;56(2):S108–S109.
7 Colletti RB. A learning health system to transform the health, care and cost of IBD. Journal of Crohn’s and Colitis. 2014;8 SUPPL. 2:S425–S426.
8 Duda MA, Riopelle RJ, Brown J. From theory to practice: an illustrative case for selecting evidence-based practices and building implementation capacity in 3 Canadian health jurisdictions. Evid Polciy. 2014;10(4):565–577.
9 Han DP. How a manufacturing process transformed healthcare delivery. Medical economics. 2013;90(14):31–34.
10 Heinssen R, McGorry P, Nordentoft M. RAISE 2.0 - Establishing a national early psychosis intervention network in the u.S. Early Intervention in Psychiatry. 2016;10 Supplement 1:4.
11 Hou JXAWJSJKMGIGJCGWAVSLMJMTQCJCDM. P-129 CCFA Quality of Care Breakthrough Series Collaborative. [Internet Resource; Article; Computer File]. 2017; 1 online resource. Available at: https://nls.ldls.org.uk/welcome.html?ark:/81055/vdc_100048835393.0x000008
12 Massoud MRN, G.A.; Nolan, K.; Schall, M.W.; Sevin, C. A Framework for Spread: From Local Improvements to System-Wide Change. IHI Innovation Series White Paper Institute for Healthcare Improvement. 2006.
13 McIntosh B. Developing a national learning health system. British Journal of Health Care Management. 2017;23(7):304–305.
14 Melmed GMAKBHCJDJHGJMLMLDRDSSHJTATQYZ. P-043 Feasibility of a Multicenter, Collaborative, Longitudinal, Quality Improvement Learning Health System for Adult IBD Care. [Internet Resource; Article; Computer File]. 2017; 1 online resource. Available at: https://nls.ldls.org.uk/welcome.html?ark:/81055/vdc_100048835340.0x00003b
15 Moore SM. Exploring Systems Thinking as an Underlying Mechanism in Improving Healthy Lifestyles of Overw8 and Obese Adolescents: Psychometrics of the Systems Thinking Scale for Adolescent Behavior Change. Circulation. 2016;133.
16 Mowry E, Krupp L, Bermel R, . The multiple sclerosis partners advancing technology and health solutions (MS PATHS) patient cohort. Multiple Sclerosis Journal. 2017;23(3 Supplement 1):120–121.
17 Nolan KMSMW. Spreading improvement across your health care organization. Oak Brook, Ill.: Joint Commission Resources: Cambridge, MA; 2007.
18 Powell DS, R. Leading System-Wide Change: Reducing Door-To-Provider Time for Emergency Room Patients. Healthcare Systems Process Improvement. 2015.
19 Ramirez E. Connected Health Care. In: Health Care in Transition; Variation: Health Care in Transition.: Nova Science Publishers, Inc; 2016: http://public.eblib.com/choice/publicfullrecord.aspx?p=4591548
20 Rocque GB, Partridge EE. Sustainabity of patient navigation programs: Lessons learned from a Medicare innovation project. Cancer Epidemiology Biomarkers and Prevention. 2015;24(10):2014–2011.
21 Sale T, Melton R, Hayden-Lewis K, Usher C. Integrating coordinated specialty care in the U.S.: Oregon’s experience. Early Intervention in Psychiatry. 2016;10 Supplement 1:58.
22 Williams MS. Implementation Science and Integration into Healthcare Systems. In: Genomic and Precision Medicine: Foundations, Translation, and Implementation: Third Edition. Elsevier Inc.; 2016:217–232.

## Not healthcare delivery (n=7)

1 2. Abrams JS, Mooney M, Zwiebel J, Friedman S. Improving the protocol implementation process: the National Cancer Institute’s response. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2014;32(23):2515–2516.25002734
2 Bennett GG, Shelton RC. Extending Our Reach for Greater Impact. Health education & behavior: the official publication of the Society for Public Health Education. 2017;44(6):835–838.29025265
3 Doshi JA, Willke RJ. Advancing High-Quality Value Assessments of Health Care Interventions. Value in health: the journal of the International Society for Pharmacoeconomics and Outcomes Research. 2017;20(2):181–184.28237192
4 Lin SY, Schillinger E, Irby DM. Value-Added Medical Education: Engaging Future Doctors to Transform Health Care Delivery Today. Journal of General Internal Medicine. 2015;30(2):150–151.25217209
5 Milat AJ, King L, Newson R, . Increasing the scale and adoption of population health interventions: experiences and perspectives of policy makers, practitioners, and researchers. Health research policy and systems. 2014;12:18.24735455
6 Rosas LG, Lv N, Azar K, Xiao L, Yank V, Ma J. Applying the Pragmatic-Explanatory Continuum Indicator Summary Model in a Primary Care-Based Lifestyle Intervention Trial. American journal of preventive medicine. 2015;49(3 Suppl 2):S208–214.26296556
7 Sanchez MA, Vinson CA, Porta ML, Viswanath K, Kerner JF, Glasgow RE. Evolution of Cancer Control P.L.A.N.E.T.: moving research into practice. Cancer causes & control: CCC. 2012;23(7):1205–1212.22674294

## Low income country (n=3)

1 Bjorkman J, Schulz R. On the implementation of change in national health delivery systems: a model and an application. Journal of health and human resources administration. 1981;4(2):195–227.10253890
2 Peterson S. Assessing the scale-up of child survival interventions. Lancet. 2010;375(9714):530–531.20071022
3 Renju J. A detailed review of how scaling-up a sexual and reproductive health intervention to improve young people’s health can affect the coverage and quality of its implementation. Amsterdam: Rozenberg; 2011.

## Duplicate (n=1)

Smoyer W, Embi PJ, Moffatt-Bruce S. Creating Local Learning Health Systems Think Globally, Act Locally. JAMA - Journal of the American Medical Association. 2016;316(23):2481–2482.27997662

## Otherwise not relevant to the topic of spread (n=95)

### Piloting or initial testing of interventions (n=53)

1 Balbale SN, Hill JN, Guihan M, . Evaluating implementation of methicillin-resistant Staphylococcus aureus (MRSA) prevention guidelines in spinal cord injury centers using the PARIHS framework: a mixed methods study. Implementation science: IS. 2015;10:130.26353798
2 Barber JA, Rosenheck RA, Armstrong M, Resnick SG. Monitoring the dissemination of peer support in the VA Healthcare System. Community mental health journal. 2008;44(6):433–441.18473174
3 Benn J, Burnett S, Parand A, Pinto A, Iskander S, Vincent C. Perceptions of the impact of a large-scale collaborative improvement programme: experience in the UK Safer Patients Initiative. Journal of evaluation in clinical practice. 2009;15(3):524–540.19522907
4 Benning AD-W, M.; Nwulu, U.; Ghaleb, M.; Dawson, J.; Barber, N.; Franklin, B.D.; Girling, A.; Hemming, K.; Carmalt, M.; Rudge, G.; Naicker, T.; Kotecha, A.; Derrington, M.C.; Lilford, R. Multiple component patient safety intervention in English hospitals: controlled evaluation of second phase. BMJ Innovations. 2011;342.
5 Blake SC, Kohler S, Rask K, Davis A, Naylor DV. Facilitators and barriers to 10 National Quality Forum safe practices. American journal of medical quality: the official journal of the American College of Medical Quality. 2006;21(5):323–334.16973949
6 Bölenius K, Söderberg J, Hultdin J, Lindkvist M, Brulin C, Grankvist K. Minor improvement of venous blood specimen collection practices in primary health care after a large-scale educational intervention. [Internet Resource; Archival Material]. 2013; http://urn.kb.se/resolve?urn=urn:nbn:se:umu:diva-61551
7 Chen JY, Kang N, Juarez DT, Hodges KA, Chung RS, Legorreta AP. Impact of a payfor-performance program on low performing physicians. Journal for healthcare quality: official publication of the National Association for Healthcare Quality. 2010;32(1):13–21; quiz 21–12.20151587
8 Crabtree BF, Nutting PA, Miller WL, Stange KC, Stewart EE, Jaen CR. Summary of the National Demonstration Project and recommendations for the patient-centered medical home. Annals of family medicine. 2010;8: Suppl 1:S80–90; s92.20530397
9 Dainty KN, Scales DC, Sinuff T, Zwarenstein M. Competition in collaborative clothing: a qualitative case study of influences on collaborative quality improvement in the ICU. BMJ quality & safety. 2013;22(4):317–323.
10 Damush TM, Miller KK, Plue L, . National implementation of acute stroke care centers in the Veterans Health Administration (VHA): formative evaluation of the field response. Journal of general internal medicine. 2014;29: Suppl 4:845–852.25355091
11 Evans ME, Kralovic SM, Simbartl LA, . Prevention of methicillin-resistant Staphylococcus aureus infections in spinal cord injury units. American journal of infection control. 2013;41(5):422–426.23149087
12 Foster GL, Kenward K, Hines S, Joshi MS. The Relationship of Engagement in Improvement Practices to Outcome Measures in Large-Scale Quality Improvement Initiatives. Am J Med Qual. 2017;32(4):361–368.27493200
13 Greene J, Hibbard JH, Overton V. Large performance incentives had the greatest impact on providers whose quality metrics were lowest at baseline. Health affairs (Project Hope). 2015;34(4):673–680.25847651
14 Hagedorn HJ, Rettmann N, Dieperink E, Knott A, Landon BE. A Training Model for Implementing Hepatitis Prevention Services in Substance Use Disorder Clinics: A Qualitative Evaluation. Journal of general internal medicine. 2015;30(8):1215–1221.25903992
15 Ignatowicz A, Greenfield G, Pappas Y, Car J, Majeed A, Harris M. Achieving provider engagement: providers’ perceptions of implementing and delivering integrated care. Qualitative health research. 2014;24(12):1711–1720.25212855
16 Jaen CR, Ferrer RL, Miller WL, . Patient outcomes at 26 months in the patient-centered medical home National Demonstration Project. Annals of family medicine. 2010;8: Suppl 1:S57–67; s92.20530395
17 Kauth MR, Sullivan G, Blevins D, . Employing external facilitation to implement cognitive behavioral therapy in VA clinics: a pilot study. Implementation science: IS. 2010;5:75.20942951
18 Krein SL, Bernstein SJ, Fletcher CE, . Improving eye care for veterans with diabetes: an example of using the QUERI steps to move from evidence to implementation: QUERI Series. Implementation science: IS. 2008;3:18.18353187
19 Larson ELE, E.; Cloonan, P. Sugrue, S.; Parides, M. An organizational climate intervention associated with increased handwashing and decreased nosocomial infections. Behav Med. 2000;26:14–22.10971880
20 Li P, Bahensky JA, Jaana M, Ward MM. Role of multihospital system membership in electronic medical record adoption. Health care management review. 2008;33(2):169–177.18360167
21 Lourenco T, Grant AM, Burr JM, Vale L. The introduction of new interventional procedures in the British National Health Service--a qualitative study. Health policy (Amsterdam, Netherlands). 2011;100(1):35–42.
22 Lowes LPH, G.; Newmeyer, A.; Embi, P.; Yin, H.; Smoyer, W. Learn From Every Patient: implementation and early results of a learning health system. Developmental Medicine and Child Neurology. 2016.
23 Mannion R, Goddard M, Kuhn M, Bate A. Decentralization strategies and provider incentives in healthcare: evidence from the english national health service. Applied health economics and health policy. 2005;4(1):47–54.16076238
24 Mansell S, Harris M. A double act: implementing the National Service Framework. RCM midwives: the official journal of the Royal College of Midwives. 2006;9(10):402–403.17042324
25 Marsteller JA, Woodward P, Underwood WS, Hsiao CJ, Barr MS. Design of a quality and performance improvement project for small primary care practices: reflections on the Center for Practice Innovation. Quality in primary care. 2011;19(1):49–57.
26 McAlearney AS, Hefner J, Robbins J, Garman AN. Toward a high-performance management system in health care, part 4: Using high-performance work practices to prevent central line-associated blood stream infections-a comparative case study. Health care management review. 2016;41(3):233–243.26002415
27 McGinnis JMLODA. Learning Healthcare System: Workshop Summary, IOM Roundtable on Evidence-Based Medicine. In: Variation: Online access: National Academy of Sciences National Academies Press.: National Academies Press; 2007: http://www.nap.edu/11903
28 McKnight W. For Nationwide Children’s Hospital, a Local Learning Health System Shows Global Promise. Industry Edge. 2017(April 2017).
29 Metlay JP, Camargo CA, Jr., MacKenzie T, . Cluster-randomized trial to improve antibiotic use for adults with acute respiratory infections treated in emergency departments. Annals of emergency medicine. 2007;50(3):221–230.17509729
30 Mezey M, Kobayashi M, Grossman S, Firpo A, Fulmer T, Mitty E. Nurses Improving Care to Health System Elders (NICHE): implementation of best practice models. The Journal of nursing administration. 2004;34(10):451–457.15577667
31 Nutting PA, Crabtree BF, Miller WL, Stange KC, Stewart E, Jaen C. Transforming physician practices to patient-centered medical homes: lessons from the national demonstration project. Health affairs (Project Hope). 2011;30(3):439–445.21383361
32 Nutting PA, Crabtree BF, Miller WL, Stewart EE, Stange KC, Jaen CR. Journey to the patient-centered medical home: a qualitative analysis of the experiences of practices in the National Demonstration Project. Annals of family medicine. 2010;8: Suppl 1:S45–56; s92.20530394
33 Nutting PA, Crabtree BF, Stewart EE, . Effect of facilitation on practice outcomes in the National Demonstration Project model of the patient-centered medical home. Annals of family medicine. 2010;8: Suppl 1:S33–44; s92.20530393
34 Nutting PA, Miller WL, Crabtree BF, Jaen CR, Stewart EE, Stange KC. Initial lessons from the first national demonstration project on practice transformation to a patient-centered medical home. Annals of family medicine. 2009;7(3):254–260.19433844
35 O’Connell TJ, Bassham JE, Bishop RO, . Clinical process redesign for unplanned arrivals in hospitals. The Medical journal of Australia. 2008;188:(6 Suppl):S18–22.18341471
36 Ovretveit J, Klazinga N. Learning from large-scale quality improvement through comparisons. International Journal for Quality in Health Care. 2012;24(5):463–469.22879374
37 Parekh AK, Kronick R, Tavenner M. Optimizing health for persons with multiple chronic conditions. Jama. 2014;312(12):1199–1200.25133982
38 Porteous JM, Stewart-Wynne EG, Connolly M, Crommelin PF. iSoBAR--a concept and handover checklist: the National Clinical Handover Initiative. The Medical journal of Australia. 2009;190:(11 Suppl):S152–156.19485867
39 Power M, Brewster L, Parry G, . Multimethod study of a large-scale programme to improve patient safety using a harm-free care approach. BMJ open. 2016;6(9).
40 Rattray NA, Damush TM, Luckhurst C, Bauer-Martinez CJ, Homoya BJ, Miech EJ. Prime movers: Advanced practice professionals in the role of stroke coordinator. Journal of the American Association of Nurse Practitioners. 2017;29(7):392–402.28440589
41 Rhee JJ, Zwar NA, Kemp LA. Uptake and implementation of Advance Care Planning in Australia: findings of key informant interviews. Australian health review: a publication of the Australian Hospital Association. 2012;36(1):98–104.22513028
42 Rhodes P, Giles SJ, Cook GA, . Assessment of the implementation of a national patient safety alert to reduce wrong site surgery. Quality & safety in health care. 2008;17(6):409–415.19064655
43 Rittenhouse DR, Ramsay PP, Casalino LP, McClellan S, Kandel ZK, Shortell SM. Increased Health Information Technology Adoption and Use Among Small Primary Care Physician Practices Over Time: A National Cohort Study. Annals of family medicine. 2017;15(1):56–62.28376461
44 Rosenberg KZ, J. A Simple Intervention Reduces Contamination Risk In Healthcare. American Journal of Nursing. 2016;116:64–65.
45 Ryan AM, Blustein J, Casalino LP. Medicare’s Flagship Test Of Pay-For-Performance Did Not Spur More Rapid Quality Improvement Among Low-Performing Hospitals. Health Affairs. 2012;31(4):797–805.22492897
46 Salowe RJ, O’Brien JM. NEI’s audacious goals initiative. Ophthalmology. 2014;121(3):615–616.24581751
47 Schifalacqua MM, Shepard A, Kelley W. Evidence-based practice: cost-benefit of large system implementation. Quality management in health care. 2012;21(2):74–80.22453818
48 Solomon J, Day C, Worrall A, Thompson P. Does sustained involvement in a quality network lead to improved performance? International journal of health care quality assurance. 2015;28(3):228–233.25860919
49 Stewart EE, Nutting PA, Crabtree BF, Stange KC, Miller WL, Jaen CR. Implementing the patient-centered medical home: observation and description of the national demonstration project. Annals of family medicine. 2010;8: Suppl 1:S21–32; s92.20530392
50 Walley P, Silvester K, Steyn R. Knowledge and behaviour for a sustainable improvement culture. HealthcarePapers. 2006;7(1):26–33; discussion 74–27.16914937
51 Wang L, Kuntz-Melcavage K, Forrest CB, . Development and applications of an outcomes assessment framework for care management programs in learning health systems. EGEMS (Washington, DC). 2015;3(1):1119.
52 Wise J. Hospitals and GPs are offered incentives to reduce antibiotic prescribing. BMJ (Clinical research ed). 2016;352:i1499.
53 Zanaboni P, Wootton R. Adoption of routine telemedicine in Norwegian hospitals: progress over 5 years. BMC health services research. 2016;16:496.27644324

### Pre-implementation analyses with no implementation component (n=38)

1 New star system for the NHS and style of handling poor performance--a significant step forward for improving the NHS. Journal of nursing management. 2002;10(1):55–56.
2 Aarons GA, Green AE, Willging CE, . Mixed-method study of a conceptual model of evidence-based intervention sustainment across multiple public-sector service settings. Implementation science: IS. 2014;9:183.25490886
3 Bailie J, Laycock A, Matthews V, Bailie R. System-Level Action Required for Wide-Scale Improvement in Quality of Primary Health Care: Synthesis of Feedback from an Interactive Process to Promote Dissemination and Use of Aggregated Quality of Care Data. Front Public Health. 2016;4.
4 Barengolts EI, Burke BV, Duckworth WC, Kaminsky R, Miller DR, Swislocki AL. Adoption of a new technology in a Veterans Affairs national formulary system with local implementation: the insulin glargine example. Managed care interface. 2007;20(3):37–44, 57.
5 Bashshur RL, Shannon GW, Krupinski EA, . National telemedicine initiatives: essential to healthcare reform. Telemedicine journal and e-health: the official journal of the American Telemedicine Association. 2009;15(6):600–610.19534591
6 Bhavnani SP, Parakh K, Atreja A, . 2017 Roadmap for Innovation-ACC Health Policy Statement on Healthcare Transformation in the Era of Digital Health, Big Data, and Precision Health A Report of the American College of Cardiology Task Force on Health Policy Statements and Systems of Care. J Am Coll Cardiol. 2017;70(21):2696–2718.29169478
7 Charns MP, Egede LE, Rumsfeld JS, McGlynn GC, Yano EM. Advancing Partnered Research in the VA Healthcare System: The Pursuit of Increased Research Engagement, Responsiveness, and Impact. Journal of General Internal Medicine. 2014;29:S811–S813.
8 Charns MP, Foster MK, Alligood EC, . Multilevel interventions: measurement and measures. Journal of the National Cancer Institute Monographs. 2012;2012(44):67–77.22623598
9 Cherry JC. Focus less on technology, more on workflow and people. Intel-GE care innovations has developed a four-phase approach to help healthcare organizations prepare for and implement new technology. Health management technology. 2012;33(3):26–27.
10 Clancy CM. Physician leadership for high-quality care. Chest. 2009;136(6):1452–1454.19995761
11 Fischer MA. The National e-Prescribing Patient Safety Initiative: removing one hurdle, confronting others. Drug safety. 2007;30(6):461–464.17536873
12 Fortney JC, Owen RR. Increasing treatment engagement for persons with serious mental illness using personal health records. The American journal of psychiatry. 2014;171(3):259–261.24585327
13 Gifford E, Tavakoli S, Wisdom J, Hamlett-Berry K. Implementation of smoking cessation treatment in VHA substance use disorder residential treatment programs. Psychiatric services (Washington, DC). 2015;66(3):295–302.
14 Gonnering RS. Fostering innovation. Ophthalmic plastic and reconstructive surgery. 2014;30(6):449.25192330
15 Goodrich GL, Lueck AH. Vision rehabilitation services at a crossroads. Journal of Visual Impairment & Blindness. 2010;104(10):593.
16 Grant RW, Uratsu CS, Estacio KR, . Pre-Visit Prioritization for complex patients with diabetes: Randomized trial design and implementation within an integrated health care system. Contemporary clinical trials. 2016;47:196–201.26820612
17 Ham C. Supporting poorly performing NHS hospitals to improve. BMJ (Clinical research ed). 2013;347:f5830.
18 Ho PM, Maynard C, Starks H, Sun H, Sloan K, Sales A. Outcomes in patients with coronary heart disease who do not undergo lipid testing. The American journal of cardiology. 2003;91(8):986–988, a987.12686344
19 Holly TA. A world view of nuclear cardiology practices: Think globally, act locally. Journal of nuclear cardiology: official publication of the American Society of Nuclear Cardiology. 2017;24(3):860–861.26917419
20 Husk J. Achieving changes in practice from national audit: national audit of the organization of services for falls and bone health in older people. Journal of evaluation in clinical practice. 2008;14(6):974–978.18462284
21 Kent TA. Predicting outcome of IV thrombolysis-treated ischemic stroke patients: the DRAGON score. Neurology. 2012;78(17):1368.22529207
22 Kent TA, Rutherford DG, Breier JI, Papanicoloau AC. What is the evidence for use dependent learning after stroke? Stroke. 2009;40:(3 Suppl):S139–140.19064775
23 Khuri SF, Henderson WG, Daley J, . Successful implementation of the Department of Veterans Affairs’ National Surgical Quality Improvement Program in the private sector: the Patient Safety in Surgery study. Annals of surgery. 2008;248(2):329–336.18650645
24 Kingston J, Katsaros J, Vu Y, Goodrich GL. Neurological vision rehabilitation: description and case study. Journal of Visual Impairment & Blindness. 2010;104(10):603.
25 Kopjar B, Sales AE, Pineros SL, Sun H, Li YF, Hedeen AN. Comparison of characteristics of patients with coronary heart disease receiving lipid-lowering therapy versus those not receiving such therapy. The American journal of cardiology. 2003;91(11):1352–1354.12767433
26 Lopez L. Integrated delivery systems … managed care organizations, hospitals, doctors, and insurers are developing new entities to compete for business. The state of health care in America. 1995:31–35.10168068
27 McIntyre K, Shojania KG. The challenges of quality improvement reports and the urgent need for more of them. Thorax. 2011;66(12):1020–1022.21856698
28 Miller RR, Li YF, Sun H, . Underuse of cardioprotective medications in patients prior to acute myocardial infarction. The American journal of cardiology. 2003;92(2):209–211.12860227
29 Pines JM, Hollander JE, Lee H, Everett WW, Uscher-Pines L, Metlay JP. Emergency department operational changes in response to pay-for-performance and antibiotic timing in pneumonia. Academic emergency medicine: official journal of the Society for Academic Emergency Medicine. 2007;14(6):545–548.17470905
30 Raleigh VS, Frosini F, Sizmur S, Graham C. Do some trusts deliver a consistently better experience for patients? An analysis of patient experience across acute care surveys in English NHS trusts. BMJ quality & safety. 2012;21(5):381–390.
31 Resnick SG, Rosenheck RA, Drebing CE. What makes vocational rehabilitation effective? Program characteristics versus employment outcomes nationally in VA. Psychol Serv. 2006;3(4):239.
32 Rose AJ, Petrakis BA, Callahan P, . Organizational characteristics of high- and low-performing anticoagulation clinics in the Veterans Health Administration. Health services research. 2012;47(4):1541–1560.22299722
33 Scott WR. Embedding the examination of multilevel factors in an organization field context. Journal of the National Cancer Institute Monographs. 2012;2012(44):32–33.22623593
34 Shneiderman B. A national initiative for social participation. Science (New York, NY). 2009;323(5920):1426–1427.
35 Slonim AD, Maraccini AM. Necessities for the Assessment and Delivery of Value-Based Critical Care: Empirical Evidence and Systemic Considerations. Critical care medicine. 2018;46(1):155–156.29252941
36 Terry KD. Clinical integration sets the stage for positive change. Goal is to promote higher-quality, more cost-efficient patient services by better coordinating care across a continuum of conditions, providers, settings and time. Health management technology. 2012;33(9):16–17.
37 Venes D. The evolving science of translating research evidence into clinical practice. Evidence-based medicine. 2007;12(4):102.17885151
38 Yano EM. Teaching Commentary on “A Primary Care-Based Multidisciplinary Readmission Prevention Program”: Essential Aspects of Comparability and Context in Practice-Based Program Evaluation. Journal of General Internal Medicine. 2014;29(5):805–807.24627269

### Other topics not relevant to spread (eg, medical education programming, n=4)

1 Harris A, Tallia A, Tallia A, . Health system change and academic departments. Annals of family medicine. 2014;12(2):180–181.24615320
2 Theile DE, Scott IA, Martin JH, Gavrilidis A. Enabling the success of academic health science centres in Australia: where is the leadership? Med J Aust. 2014;201(11):636–638.25495302
3 Washington AE, Coye MJ, Feinberg DT. Academic health centers and the evolution of the health care system. Jama. 2013;310(18):1929–1930.24219942
4 Yu H. On academic health system. Journal of evidence-based medicine. 2013;6(2):71–73.23829798