# APPENDIX D QUERI and SAIL Templates Used in Analysis

QUERI

Project/Transcript ID | What makes sites hard to engage? | Strategies/facilitators to engagement (or lack thereof, include mandates and other external factors, changes over time to implementation strategy) | Description of intervention (how much effort on part of sites, fidelity of practice/changes over time) | Timeline (How long different steps took, and was full scale/spread achieved?) | Other stuff

SAIL

Project/Transcript ID | Why started/what motivated/initial catalyst? | Overall approach over time?; Key strategies used, changes over time, specific metrics focused on, where did they find materials or resources (eg homegrown or from a group or person) | How used analytics/data/coding in process | Who is involved?; Leadership role/activities, autonomy of people involved to make decisions, stability of personnel | Other stuff/activities