# APPENDIX C SAIL Data Exemplars

Fiscal year; Quarter | | ‘11 | ‘12 | | | | ‘13 | | | | ‘14 | | | | ‘15 | | | | ‘16 | | | | ‘17
Fiscal year; Quarter | | * | 1 | 2 | 3 | 4 | 1 | 2 | 3 | 4 | 1 | 2 | 3 | 4 | 1 | 2 | 3 | 4 | 1 | 2 | 3 | 4 | 1 | 2 | 3 | 4
Low quintile score examples | | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5
Low quintile score examples | | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 4 | 4 | 3 | 3 | 3 | 4
Low quintile score examples | | 4 | 5 | 4 | 5 | 5 | 4 | 5 | 5 | 3 | 4 | 4 | 4 | 4 | 4 | 5 | 5 | 5 | 5 | 5 | 5 | 4 | 4 | 4 | 4 | 4
Low quintile score examples | | 5 | 5 | 5 | 5 | 5 | 5 | 4 | 3 | 4 | 3 | 3 | 4 | 4 | 4 | 4 | 5 | 4 | 3 | 4 | 3 | 3 | 3 | 3 | 3 | 3
Low quintile score examples | | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 4 | 5 | 5 | 5 | 5 | 5
High quintile score examples | | 1 | 1 | 1 | 2 | 2 | 3 | 3 | 3 | 3 | 2 | 2 | 2 | 2 | 2 | 3 | 3 | 2 | 2 | 2 | 1 | 1 | 1 | 2 | 2 | 2
High quintile score examples | | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1
High quintile score examples | | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 3 | 3
High quintile score examples | | 2 | 3 | 3 | 3 | 2 | 2 | 3 | 3 | 2 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 2 | 2 | 2 | 3 | 3
High quintile score examples | | 2 | 2 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 2 | 2 | 2 | 2 | 2 | 1 | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 1
Improving scores (n=16) | A | 4 | 4 | 3 | 3 | 3 | 3 | 3 | 4 | 3 | 4 | 4 | 3 | 3 | 2 | 2 | 2 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1
Improving scores (n=16) | B | 5 | 4 | 4 | 4 | 5 | 5 | 5 | 4 | 3 | 3 | 4 | 4 | 4 | 4 | 4 | 3 | 2 | 3 | 3 | 3 | 3 | 3 | 3 | 3 | 3
Improving scores (n=16) | C | 4 | 4 | 4 | 4 | 3 | 3 | 4 | 4 | 4 | 4 | 4 | 3 | 4 | 4 | 4 | 3 | 3 | 3 | 2 | 1 | 1 | 1 | 1 | 1 | 1
Improving scores (n=16) | D | 4 | 4 | 5 | 5 | 5 | 5 | 5 | 4 | 5 | 4 | 3 | 2 | 3 | 3 | 3 | 4 | 3 | 3 | 3 | 3 | 3 | 2 | 2 | 2 | 1
Improving scores (n=16) | E | 5 | 4 | 4 | 4 | 4 | 3 | 2 | 2 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1
Improving scores (n=16) | F | 3 | 3 | 3 | 3 | 4 | 5 | 5 | 5 | 5 | 4 | 5 | 5 | 5 | 5 | 5 | 3 | 3 | 2 | 2 | 2 | 2 | 1 | 2 | 2 | 2
Improving scores (n=16) | G | 4 | 4 | 4 | 4 | 4 | 5 | 4 | 4 | 5 | 4 | 5 | 4 | 4 | 5 | 5 | 5 | 5 | 4 | 4 | 3 | 3 | 3 | 3 | 2 | 3
Improving scores (n=16) | H | 4 | 4 | 4 | 5 | 4 | 4 | 3 | 2 | 2 | 3 | 3 | 4 | 3 | 4 | 4 | 4 | 4 | 4 | 3 | 2 | 2 | 2 | 2 | 3 | 3
Improving scores (n=16) | I | 3 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 5 | 5 | 5 | 4 | 4 | 3 | 3 | 2 | 3 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2
Improving scores (n=16) | J | 4 | 4 | 3 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 3 | 3 | 3 | 3 | 3 | 3 | 3 | 2 | 3 | 3 | 3 | 3 | 2 | 3
Improving scores (n=16) | K | 4 | 4 | 4 | 4 | 3 | 3 | 4 | 3 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 3 | 3 | 2 | 1 | 2 | 1 | 2 | 3
Improving scores (n=16) | L | 3 | 3 | 3 | 2 | 3 | 4 | 4 | 4 | 5 | 5 | 4 | 4 | 5 | 5 | 5 | 5 | 4 | 3 | 3 | 3 | 2 | 2 | 1 | 1 | 1
Improving scores (n=16) | M | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 3 | 3 | 2 | 3 | 3 | 4 | 4 | 4 | 4 | 4 | 3 | 3 | 2 | 2
Improving scores (n=16) | N | 4 | 3 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 4 | 3 | 2 | 2 | 2
Improving scores (n=16) | O | 3 | 3 | 3 | 3 | 4 | 4 | 4 | 3 | 3 | 3 | 3 | 3 | 4 | 4 | 3 | 3 | 1 | 1 | 2 | 2 | 2 | 1 | 1 | 1 | 1
Improving scores (n=16) | P | 3 | 3 | 2 | 3 | 3 | 4 | 4 | 4 | 3 | 3 | 3 | 4 | 4 | 4 | 4 | 4 | 3 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2
Changing score examples, other | | 1 | 1 | 1 | 1 | 1 | 1 | 2 | 2 | 2 | 3 | 3 | 3 | 3 | 3 | 3 | 4 | 4 | 5 | 4 | 5 | 5 | 5 | 5 | 5 | 5
Changing score examples, other | | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 1 | 1 | 1 | 1 | 2 | 3 | 2 | 1 | 1 | 1 | 2 | 2 | 3 | 4 | 4 | 3
Changing score examples, other | | 2 | 2 | 1 | 1 | 1 | 2 | 4 | 4 | 5 | 4 | 4 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5
Changing score examples, other | | 3 | 3 | 3 | 3 | 3 | 2 | 2 | 3 | 4 | 4 | 3 | 2 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 2
Changing score examples, other | | 3 | 4 | 4 | 4 | 4 | 3 | 3 | 3 | 2 | 4 | 4 | 4 | 4 | 5 | 5 | 5 | 5 | 5 | 4 | 4 | 5 | 4 | 5 | 5 | 5
Changing score examples, other | | 3 | 2 | 3 | 3 | 2 | 2 | 2 | 2 | 4 | 4 | 5 | 4 | 3 | 3 | 3 | 3 | 4 | 4 | 4 | 4 | 5 | 5 | 5 | 5 | 4
Changing score examples, other | | 4 | 3 | 3 | 3 | 2 | 3 | 2 | 2 | 3 | 3 | 3 | 3 | 3 | 3 | 4 | 4 | 4 | 4 | 4 | 4 | 4 | 5 | 4 | 3 | 3
Changing score examples, other | | 4 | 4 | 5 | 4 | 4 | 5 | 5 | 5 | 5 | 4 | 3 | 3 | 2 | 3 | 3 | 4 | 3 | 3 | 4 | 4 | 4 | 5 | 4 | 4 | 4
Changing score examples, other | | 4 | 4 | 4 | 4 | 3 | 2 | 3 | 3 | 4 | 3 | 3 | 2 | 2 | 3 | 2 | 3 | 4 | 4 | 4 | 4 | 4 | 4 | 5 | 5 | 5
Changing score examples, other | | 5 | 5 | 5 | 4 | 4 | 4 | 4 | 4 | 3 | 3 | 2 | 3 | 4 | 4 | 5 | 5 | 5 | 5 | 4 | 4 | 3 | 3 | 4 | 5 | 5
Changing score examples, other | | 5 | 2 | 1 | 2 | 2 | 5 | 5 | 4 | 5 | 5 | 5 | 4 | 4 | 4 | 5 | 5 | 5 | 4 | 5 | 5 | 4 | 5 | 5 | 5 | 5

* Data were only collected once in FY2011