# APPENDIX B Interview Guide Questions

## INTERVIEW GUIDE QUESTIONS – QUERI Interviewees

[QUESTIONS FOLLOW INTERVIEW GUIDE INTRODUCTORY SECTION]

We understand you were the Principal Investigator for the QUERI project [PROJECT NAME]. We are particularly interested in this project because it was an example of spreading an existing project.

1. Please tell us about your experience with this project.
2. Can you describe the strategy for the spread of [INITIATIVE/PRACTICE]?
  a. Who was involved in making the decision to spread beyond the earlier sites?
  b. Who was involved in the spread effort itself?
3. What factors [national/regional/local/site specific] facilitated the spread of the project?
4. What factors [national/regional/local/site specific] impeded the spread of the project?
5. Were certain sites more difficult to engage?
  a. If so, what factors contributed to this?
  b. Potential factors to probe: leadership, resources, lines of reporting/authority to make changes, structural factors
    i. Was low performance a factor?
    ii. Were there specific challenges?
  c. Were there specific strategies used for engaging or working with this group of sites?
6. During spread efforts, was fidelity of implementation monitored?
  a. If so, how?
  b. During spread, was fidelity to original model strong?
  c. Were modifications made to the model or strategy?
    i. If so, why?
    ii. What changes to the strategy were most successful?
    iii. Which were less successful?
7. From the time the idea for [INITIATIVE/PRACTICE] was first conceived, could you briefly describe the key time points in the process?

Eg, initial idea, first piloting/demo, early spread, full/national roll-out

Is there anything else you would like to share with us, particularly about working with hard-to-engage sites? Please feel free to draw on other experience you may have had.

Thank you for your time!

## INTERVIEW GUIDE QUESTIONS – SAIL Improvers

[QUESTIONS FOLLOW INTERVIEW GUIDE INTRODUCTORY SECTION]

The [SITE] facility had improved its overall SAIL score around [YEAR]. We are particularly interested in your site because it was able to make these improvements and maintain them. We understand that you were there during these changes, and would like to hear, from your perspective, more about how this improvement happened.

1. Can you describe your role?
2. From your perspective, what is the story of the improvement during [BEGINNING YEAR] until now? How did the improvement happen?
3. What were one or 2 underlying approaches that were necessary to make the change happen?
4. What factors at your site contributed to the improvement?
  Leadership changes, leadership support/engagement, structure, lines of reporting, analytics/data, etc.
5. Did you specifically focus on any particular metrics? Did this change over time?
6. Did you have specific interventions or tools your site used during this improvement process? Where did they come from?
7. When did the SAIL improvement begin and what motivated it?
8. What role has the VISN played over the course of these improvements? What types of SAIL-related resources or interactions have you shared?

Is there anything else you would like to share with us?

Thank you for your time!