# Acknowledgments

This topic was developed in response to a nomination by Dr. Shereef Elnahal from the Office of Organizational Excellence (10E). The scope was further developed with input from the topic nominators (ie, Operational Partners, listed below), the ESP Coordinating Center, the review team, and the technical expert panel (TEP, listed below).

In designing the study questions and methodology at the outset of this report, the ESP consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who have requested the report to inform decision-making. They can recommend Technical Expert Panel (TEP) participants; assure VA relevance; help develop and approve final project scope and timeframe for completion; provide feedback on draft report; and provide consultation on strategies for dissemination of the report to field and relevant groups.

- Ryan Vega, MD
  Director, Diffusion of Excellence Initiative
  VA Center for Innovation
- Saurabha Bhatnagar, MD
  Acting Assistant Deputy Under Secretary for Health
  Office of Quality, Safety, and Value (10E2)

## Technical Expert Panel (TEP)

To ensure robust, scientifically relevant work, the TEP guides topic refinement; provides input on key questions and eligibility criteria, advising on substantive issues or possibly overlooked areas of research; assures VA relevance; and provides feedback on work in progress. TEP members are listed below:

- Nick Bowersox, PhD, ABPP
  Director, QUERI Center for Implementation and Evaluation Resources
- Laura Damschroder, MS, MPH
  Investigator, HSR&D Center for Clinical Management Research
- Amy Kilbourne, PhD, MPH
  Director, QUERI
- George Jackson, PhD, MHA
  Healthcare Epidemiologist, HSR&D Center for Health Services Research in Primary Care
- Joe Francis, MD, MPH
  Director, Clinical Analytics and Reporting, Office of Analytics and Business Intelligence
- Peter Almenoff, MD
  Senior Advisor, Office of the Secretary of the VA, Director, Organizational Excellence

## Peer Reviewers

The Coordinating Center sought input from external peer reviewers to review the draft report and provide feedback on the objectives, scope, methods used, perception of bias, and omitted evidence. Peer reviewers must disclose any relevant financial or non-financial conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Coordinating Center and the ESP Center work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

## Collaborators

Dr. Miake-Lye, one of the principal investigators of this project, is the Implementation Core Lead of the Care Coordination QUERI Program. The work for this project was also supported with in-kind effort by other members of the Care Coordination QUERI Program:

- Deborah Delevan, MEd, Program Coordinator, Care Coordination QUERI Program
- David Ganz, MD, PhD, Corresponding PI, Care Coordination QUERI Program