# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CIDER: Center for Information Dissemination and Education Resources
COREQ: Consolidated criteria for reporting qualitative research
HSR&D: Health Services Research and Development Service
IHI: Institute for Health Improvement
NIH: National Institutes of Health
OSVA: Office of the VA Secretary
QUERI: Quality Enhancement Research Initiative
SAIL: Strategic Analytics for Improvement and Learning
TEP: Technical Expert Panel
VHA: Veterans Health Administration
VISN: Veterans Integrated Services Networks