# REFERENCES

1 Colosi B. NSI national health care retention & RN staffing report. NSI Nursing Solutions, Inc.
2 Pellico LH, Brewer CS, Kovner CT. What newly licensed registered nurses have to say about their first experiences. Nurs Outlook. 2009;57(4):194–203. doi:10.1016/j.outlook.2008.09.008 19631061
3 Duchscher JE. Transition shock: the initial stage of role adaptation for newly graduated registered nurses. J Adv Nurs. 2009;65(5):1103–1113. doi:10.1111/j.1365-2648.2008.04898.x 19183235
4 Transition-to-Practice. Accessed October 22, 2024. https://www.acenursing.org/accreditation/transition-to-practice
5 White Meagan, Cosme Sheryl, Drown Stephanie. Revisiting the Impact of Accreditation on Transition to Practice Programs: Findings From a Replication Analysis. J Contin Educ Nurs. 2021;52(11):525–533. doi:10.3928/00220124-20211008-08 34723720
6 IOM. The Future of Nursing: Leading Change, Advancing Health.; 2010.
7 Committee on the Robert Wood Johnson Foundation Initiative on the Future of Nursing at the I of M. The Future of Nursing: Leading Change, Advancing Health. National Academies Press; 2011.
8 Rush KL, Janke R, Duchscher JE, Phillips R, Kaur S. Best practices of formal new graduate transition programs: An integrative review. Int J Nurs Stud. 2019;94:139–158. doi:10.1016/j.ijnurstu.2019.02.010 30965203
9 Brook J, Aitken L, Webb R, MacLaren J, Salmon D. Characteristics of successful interventions to reduce turnover and increase retention of early career nurses: A systematic review. Int J Nurs Stud. 2019;91:47–59. doi:10.1016/j.ijnurstu.2018.11.003 30669077
10 Bakon S, Craft J, Wirihana L, Christensen M, Barr J, Tsai L. An integrative review of graduate transition programmes: Developmental considerations for nursing management. Nurse Educ Pr. 2018;28:80–85. doi:10.1016/j.nepr.2017.10.009
11 Hampton KB, Smeltzer SC, Ross JG. Evaluating the transition from nursing student to practicing nurse: An integrative review. J Prof Nurs. 2020;36(6):551–559. doi:10.1016/j.profnurs.2020.08.002 33308555
12 Wray J, Watson R, Gibson H, Barrett D. Approaches used to enhance transition and retention for newly qualified nurses (NQNS): A rapid evidence assessment. Nurse Educ Today. 2021;98:104651. doi:10.1016/j.nedt.2020.104651 33358036
13 Kenny A, Dickson-Swift V, McKenna L, Interventions to support graduate nurse transition to practice and associated outcomes: A systematic review. Nurse Educ Today. 2021;100:104860. doi:10.1016/j.nedt.2021.104860 33751999
14 Shea BJ, Reeves BC, Wells G, AMSTAR 2: a critical appraisal tool for systematic reviews that include randomised or non-randomised studies of healthcare interventions, or both. BMJ. 2017;358:j4008. doi:10.1136/bmj.j4008 28935701
15 Aldosari N, Pryjmachuk S, Cooke H. Newly qualified nurses’ transition from learning to doing: A scoping review. Int J Nurs Stud. 2021;113:103792. doi:10.1016/j.ijnurstu.2020.103792 33120135
16 Ke YT, Kuo CC, Hung CH. The effects of nursing preceptorship on new nurses’ competence, professional socialization, job satisfaction and retention: A systematic review. J Adv Nurs. 2017;73(10):2296–2305. doi:10.1111/jan.13317 28398636
17 Alshawush K, Hallett N, Bradbury-Jones C. The impact of transition programmes on workplace bullying, violence, stress and resilience for students and new graduate nurses: A scoping review. J Clin Nurs. 2022;31(17–18):2398–2417. doi:10.1111/jocn.16124 34811826
18 Asber SR. Retention Outcomes of New Graduate Nurse Residency Programs: An Integrative Review. J Nurs Adm. 2019;49(9):430–435. doi:10.1097/nna.0000000000000780 31436741
19 Chant KJ, Westendorf DS. Nurse Residency Programs: Key Components for Sustainability. J Nurses Prof Dev. 2019;35(4):185–192. doi:10.1097/NND.0000000000000560 31169756
20 Eckerson CM. The impact of nurse residency programs in the United States on improving retention and satisfaction of new nurse hires: An evidence-based literature review. Nurse Educ Today. 2018;71:84–90. doi:10.1016/j.nedt.2018.09.003 30268073
21 Ackerson K, Stiles KA. Value of Nurse Residency Programs in Retaining New Graduate Nurses and Their Potential Effect on the Nursing Shortage. J Contin Educ Nurs. 2018;49(6):282–288. doi:10.3928/00220124-20180517-09 29847687
22 Aparício C, Nicholson J. Do preceptorship and clinical supervision programmes support the retention of nurses? Br J Nurs. 2020;29(20):1192–1197. doi:10.12968/bjon.2020.29.20.1192 33180628
23 Cochran C. Effectiveness and Best Practice Of Nurse Residency Programs: A Literature Review. MEDSURG Nurs. 2017;26(1):53–63.30351576
24 Hoover J, Koon AD, Rosser EN, Rao KD. Mentoring the working nurse: a scoping review. Hum Resour Health. 2020;18(1):52. doi:10.1186/s12960-020-00491-x 32727573
25 Letourneau RM, Fater KH. Nurse Residency Programs: An integrative Review of the Literature. Nurs Educ Perspect. 2015;36(2):96–101. doi:10.5480/13-1229 29194133
26 Tyndall DE, Firnhaber GC, Scott ES. The Impact of New Graduate Nurse Transition Programs on Competency Development and Patient Safety: An Integrative Review. Adv Nurs Sci. 2018;41(4):E26–e52. doi:10.1097/ans.0000000000000217
27 Van Camp J, Chappy S. The Effectiveness of Nurse Residency Programs on Retention: A Systematic Review. Aorn J. 2017;106(2):128–144. doi:10.1016/j.aorn.2017.06.003 28755665
28 Surveys — Casey-Fink Surveys. Accessed October 22, 2024. https://www.caseyfinksurveys.com/surveys
29 Kowalski S, Cross CL. Preliminary outcomes of a local residency programme for new graduate registered nurses. J Nurs Manag. 2010;18(1):96–104. doi:10.1111/j.1365-2834.2009.01056.x 20465735
30 Olson-Sitki K, Wendler MC, Forbes G. Evaluating the impact of a nurse residency program for newly graduated registered nurses. J Nurses Staff Dev. 2012;28(4):156–162. doi:10.1097/NND.0b013e31825dfb4c 22821016