# ACKNOWLEDGMENTS

The authors are grateful to Emily Lawson, MSLIS, AHIP, Research and Consulting Librarian at RAND Corporation for literature searching, and the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who help ensure relevance of the review topic to the VA, contribute to the development of and approve final project scope and timeframe for completion, provide feedback on the draft report, and provide consultation on strategies for dissemination of the report to the field and relevant groups.

- Mary Pat Couig, PhD, MPH, RN, FAAN
  Office of Nursing Services, IPA RNTTP Residency Program
  Veterans Health Administration
- Shelly Roth, DNP, RN
  Acting Associate Director RN Transition to Practice Program Workforce and Leadership Development
  VA Central Office

## Technical Expert Panel

To ensure robust, scientifically relevant work, the technical expert panel (TEP) guides topic refinement; provides input on key questions and eligibility criteria, advising on substantive issues or possibly overlooked areas of research; assures VA relevance; and provides feedback on work in progress. TEP members included:

- Jack Needleman, PhD, FAAN
  Professor, Health Policy and Management
  UCLA School of Public Health
- Susan Parker, MSN, RN, NPD-BC
  Nurse Manager, RN Residency Programs
  VA St. Louis Health Care System
- Patrick Wilcox, MSN, RN, CNL
  Manager, Nurse Residency Programs (PBNR and TTP) and VALOR
  Preceptor Coordinator
  Chair, Transition to Practice Field Advisory Committee, VA Office of Nursing Service
  William S. Middleton VA Hospital