# Executive Summary

## KEY FINDINGS

► The systematic review literature search identified 140 potentially relevant reviews on RN transition-to-practice programs (RNTTPs), of which 19 were included in the final narrative synthesis. One systematic review met the standard of high confidence, 3 reviews, 1 systematic review, 1 scoping review, and 1 integrative review met the standard of moderate confidence, and the remaining reviews were appraised as low or critically low overall confidence in the review results.
► We prioritized reporting on the conclusions for outcomes included by 2 reviews that had high or moderate confidence in the review results and were scoped to address our Key Questions most directly. While the reviews we identified in our systematic review of reviews discussed critical organizational-level outcomes and some nurse-level outcomes, patient-level outcomes were absent from the identified reviews. Both reviews emphasized the methodological issues in the available evidence, which limited best-practice recommendations and conclusions. They found that the best quality evidence, which used a mix of methodological approaches, indicated a connection between RNTTPs and increased critical thinking, competency, and retention.
► To better understand the relationship between the identified syntheses and the whole of the identified original research landscape, we constructed a crosswalk that depicted the overlap between reviews. Despite having similar scopes, there was little overlap in the included literature of identified reviews. There was no seminal study or set of studies that all review authors included, and no single review that included the majority of identified original research studies was identified. Given the indicators that these reviews did not consistently and fully represent the existing evidence base of original research studies, we conducted our literature search, which identified additional original research studies not included in the prior syntheses.
► Multi-component (ie, bundled) RNTTPs may be helpful, but the specific arrangement of components and methods of choosing components to match specific contexts remain unclear. There appeared to be a set of key components represented in the published evidence syntheses, including a defined resource person (eg, mentor, clinical coach, navigator, preceptor), mentorship, peer support opportunities, education/professional development, assessment, and workplace environment.
► Many of the evidence syntheses discussed program length to some degree. However, since strong comparative studies or other rigorous evaluations were lacking, the evidence for program length was inconclusive, with published evidence syntheses suggesting similar lengths around 6–12 months.

First-year registered nurses (RNs) have the highest turnover rate of all hospital-based RNs. New graduate RNs often express that they experience many stages of internal conflict at the start of their nursing careers, despite having completed rigorous academic programs and extensive clinical experience. New graduate RNs can benefit from comprehensive RNTTPs that assist with becoming acquainted with the RN role and gaining an identity as a professional RN, which may help improve retention among new RNs.

Comprehensive RNTTPs are different from narrowly focused programs (eg, mentorships) or programs of shorter duration (eg, traditional orientations, preceptorships). Through accreditation, RNTTPs have continued to improve and advance, emphasizing evidence-based practice, quality improvement, professional development, and competency-based evaluations. While multiple accrediting bodies exist, RNTTP characteristics and implementation practices vary, which has created uncertainty among nurse leaders and administrators about the best practices for training new graduate RNs.

When accreditation organizations were first established, the Institute of Medicine (IOM) published The Future of Nursing: Leading Change, Advancing Health in 2011, in which it recommended that the federal government, state boards of nursing, accreditation bodies, and health care organizations implement and support RNTTPs. The IOM also recommended that key outcomes (eg, retention, expanding competencies, and patient outcomes) be included in RNTTP evaluation efforts. Rigorously evaluating RNTTPs would allow for comparisons between different programs, which help decision-makers determine best practices.

## CURRENT REVIEW

### Review Purpose

Numerous reviews of RNTTPs have been conducted but often included a mix of RNTTPs, traditional orientations, and mentorship programs. In addition, the ever-growing number of reviews that looked directly at residency and RNTTPs need to be summarized. We conducted a systematic review of published evidence syntheses on RNTTPs to support the Office of Nursing Services (ONS) as they plan for the continued sustainment, evolution, and evaluation of VA’s national RNTTP implementation.

### Methods

The following key questions were the focus of this review:

- Key Question 1: Are RNTTPs for newly graduated, entry-to-practice RNs effective for improving organizational, nurse, and patient outcomes?
- Key Question 2: What are the characteristics of effective RNTTPs (eg, program components, program length) for newly graduated, entry-to-practice RNs?

We included literature evaluating RNTTP or nurse residency programs specifically designed for newly graduated, entry-to-practice RNs to provide support or preceptorship during the first 12 months of employment following graduation and/or licensure for entry-to-practice. Programs must be 6 months or longer, with some in-person component; entirely remote or online/virtual programs were not included. Syntheses including systematic reviews, integrative reviews, and other reviews using a formal review methodology were included in the systematic review of reviews.

Our team conducted searches using terms relating to “transition to practice” or “new graduate nurse” or “transitional support” or “Education, Nursing, Graduate” with a systematic review delimiter in PubMed/MEDLINE and CINAHL Plus from 1/1/15–12/15/22 for systematic reviews. We limited the search to published and indexed articles available in the English language. Additional citations were identified from hand-searching reference lists of identified evidence syntheses and consultation with content experts. English-language titles, abstracts, and full-text articles were independently reviewed by 2 investigators, and disagreements were resolved by consensus. All data were abstracted by 2 reviewers independently. Any discrepancies in data abstraction were resolved by group discussion.

The quality of each published evidence synthesis was assessed using a modified version of the A MeaSurement Tool to Assess Systematic Reviews 2 (AMSTAR2) criteria to critically appraise reviews and categorized the overall confidence in the results of each review as high, moderate, low, or critically low. No reviews were excluded from our analysis based on AMSTAR2 appraisal.

We synthesized findings of our systematic review of reviews using a narrative and visual approach. We first described the reviews we identified, their relevant findings for each key question, and how existing reviews’ coverage of original research studies aligns with the breadth of evidence in this area.

### Future Research

Future work for evidence synthesis could include:

- Quantitatively analyzing comparable data from original research studies to pool smaller studies across key outcomes, while rigorously appraising risk of bias and applying certainty of evidence to resulting conclusions.
- Systematically gathering data about program components, such as program length, instruments and measures used, size/scale of program implementation beyond single versus multi-site, and other key characteristics.

However, given the widescale methodological limitations of the existing original research evidence base, we recommend conducting strong, rigorous evaluations and new original research studies on RNTTPs that take into account the recommendations of many of the included reviews, such as:

- Standardized outcome measurement that is critical for assessing typical outcomes at the nurse and organizational levels.
- Rigorous and sophisticated evaluation study designs to incorporate comparator groups, longitudinal designs, and/or multiple sites, assess organizational context, test adaptations and components, and use both comparative and mixed methods design. The field of implementation science has many critical advancements that would be helpful for advancing the study of RNTTP programs.
- Patient outcomes and economic analyses to explore the potential benefits that RNTTP programs might offer.

## CONCLUSIONS

Since the IOM report’s call to action, RNTTPs have been piloted and developed in systems across the country. These programs now deserve rigorous evaluation using sophisticated methodology to answer critical questions about their implementation and sustainment. Because RNTTPs are touted as potentially alleviating critical RN staffing shortages and supporting the development of the nursing workforce's future, the benefits of these programs should be documented, and best practices should be ascertained so they can be scaled and sustained.