# DISCUSSION

In this systematic review of reviews, we identified 19 published evidence syntheses, most of which were integrative reviews, and most of which were appraised as having low or critically low overall confidence in the results of their review. Two reviews were the most informative for our key questions: a systematic review appraised as high confidence in the results of their review that evaluated characteristics of a myriad of related interventions to increase early career RN retention,^9^ as well as an integrative review that was directly overlapping in scope with our review, which sought to explore best practices for RNTTP programs.^8^ Aside from the low confidence in many of the reviews, the other critical challenge for this systematic review of reviews was the lack of overlap between the identified original research within the reviews and the potential missing coverage across original research studies not included in reviews.

While the reviews we identified in our systematic review of reviews did discuss critical organizational-level outcomes and some nurse-level outcomes, patient-level outcomes were absent from the identified reviews. Both reviews we focused on emphasized the methodological issues in the available evidence, which limited best-practice recommendations and conclusions.^8,9^ They found that the best quality evidence, which used a mix of methodological approaches, indicates a connection between RNTTPs and more critical thinking, competency, and retention, but that more rigorous evaluations are necessary to establish estimates of effect size with an acceptable strength of evidence.

Multi-component (ie, bundled) RNTTPs may be helpful,^8^ but the specific arrangement of components and how to choose components to match specific contexts remains unclear. There appeared to be a set of key components that were represented in the published evidence syntheses, including a defined resource person (eg, mentor, clinical coach, navigator, preceptor), mentorship, peer support opportunities, education/training, assessment, and workplace environment. Many of the evidence syntheses discussed program length to some degree. However, because strong comparative studies or other published evidence evaluations were lacking, the evidence for program length was inconclusive, with published evidence synthesis reviews suggesting similar lengths around 6–12 months. Because good quality reviews did not include literature across the full span of original research we identified, or even half of the identified literature, how components and program length relate to program success is unclear. Our recommendations for future research aim to help improve this knowledge gap.

Limitations

Our systematic review of reviews aimed to orient readers to the large volume of published reviews and original research literature related to RNTTP programs. Most of the reviews we identified and the original research studies they included had substantial limitations. At the review level, the low methodological quality of the majority of the included reviews limited our confidence in their findings. Compounding the methodological quality issues were the underlying methodological limitations of the original research studies, including small sample sizes, lack of comparison groups, and other critical issues.

Aside from the limitations in the included literature, our review had 2 main limitations that deserve mention. The first limitation, inherent in all systematic reviews of reviews and umbrella reviews, is a reliance on prior synthesis efforts as the basis of our analysis. This was especially concerning given the critical methodological issues we observed in many of the identified reviews. While synthesizing data from original research studies would have been a more direct approach, this was not feasible due to the volume of work in this space. Having now conducted both a systematic review of reviews and recognizing the lack of overlap of original research studies across reviews, the preliminary groundwork for a deeper analysis of original research studies has been accomplished. The second limitation is publication bias. Given the common use of RNTTPs in a variety of health care settings, the published literature in this space may not accurately reflect the total experiences with RNTTPs at large. The RNTTPs captured in published evaluations or research projects may be qualitatively different than those that remain unpublished.

## FUTURE RESEARCH

Both new original research and additional evidence synthesis work could reap benefits in solidifying our understanding of RNTTPs. Future work for evidence synthesis could include:

- Quantitatively analyzing comparable data from original research studies to pool smaller studies across key outcomes, while rigorously appraising risk of bias and applying certainty of evidence to resulting conclusions.
- Systematically gathering data about program components, such as program length, instruments and measures used, size/scale of program implementation beyond single versus multi-site, and other key characteristics.

However, given the widescale methodological limitations of the existing original research evidence base, we recommend conducting strong, rigorous evaluations and new original research studies on RNTTPs that take into account the recommendations of many of the included reviews, such as:

- Standardized outcome measurement that is critical for assessing typical outcomes at the nurse and organizational levels.
- Rigorous and sophisticated evaluation study designs to incorporate comparator groups, longitudinal designs, and/or multiple sites, assess organizational context, test adaptations and components, and use both comparative and mixed methods design. The field of implementation science has many critical advancements that would be helpful for advancing the study of RNTTP programs.
- Patient outcomes and economic analyses to explore the potential benefits that RNTTP programs might offer.

Additionally, future implementation research that includes evaluation components may help us move beyond improving the standard outcomes addressed in the IOM report^6^ and in many existing evaluations to impacting other nursing workforce issues, such as addressing and increasing equity and diversity within the nursing workforce.

## CONCLUSIONS

Since the IOM report’s call to action, RNTTPs have been piloted and developed in health care systems across the country. These programs deserve rigorous evaluation using sophisticated methodology to answer critical questions about their implementation and sustainment. Touted as having the potential to alleviate grave nurse staffing shortages and support developing the future of the nursing workforce, these programs benefits should be documented, and best practices ascertained so that they can be scaled and sustained.