# RESULTS

## OVERVIEW OF INCLUDED REVIEWS

The systematic review literature search identified 140 potentially relevant citations, 34 of which were included for abstract screening. Of the 34 citations, 9 citations were excluded for the following reasons: only focused on 1 component of an RNTTP (eg, mentorship only, N = 5), no specific program described/evaluated (N = 2), nurse practitioners or other clinical professionals (N =1), specific clinical settings (N = 1), which resulted in 25 citations to be included for the FT screening. Six citations were excluded during the FT screening for ineligible publication types, such as commentaries or editorials. Overall, 19 reviews were included in this review (see Literature Flow Diagram, below).

Table 2 presents the details of included reviews, and key characteristics are described here. We categorized these reviews using the AMSTAR2 categories of overall confidence in a review's results and the resulting accuracy and comprehensiveness of its summary.

## LITERATURE FLOW DIAGRAM

The literature flow diagram summarizes the results of the review selection process. A full list of excluded reviews is provided in Appendix E.

Table 2 Characteristics of Included Reviews

Author, Year | Type of Review; Search Dates; Included Studies | Excerpted Relevant Findings
High (N = 1)
Brook, 2019^9^ | Systematic review; Search dates: January 2017-March 2017, repeated on April 2018; Included studies: 53 | “A wide variety of interventions and components within those interventions were identified to improve nurse retention. Promising interventions appear to be either internship/residency programmes or orientation/transition to practice programmes, lasting between 27–52 weeks, with a teaching and preceptor and mentor component.”
Moderate (N = 3)
Aldosari, 2021^15^ | Scoping review; Search dates: Not reported; Included studies: 60 | “Evidence that nursing transition programmes positively impact the transition experience is inconclusive. Some studies suggest a positive impact on newly qualified nurses’ competency, level of confidence and attrition rates; others reported no impact. There was a general consensus that newly qualified nurses still encounter difficulties when transitioning into professional practice. Most articles found were quantitative in nature, focusing on measurable outcomes of nursing transition programmes. Few investigated the experiences and perceptions of newly qualified nurses, preceptors, and managers regarding the transition to professional practice.”
Ke, 2017^16^ | Systematic review; Search dates: Through June 2015; Included studies: 6 | “The most adopted preceptorship was a fixed preceptor/preceptee model and one-on-one for 1–3-month duration. It showed that new nurses’ overall competence increased significantly due to preceptorship. Only a few studies explored the effects of preceptorship on the job satisfaction and professional socialization of new nurses.”
Rush, 2019^8^ | Integrative review; Search dates: Not reported; Included studies: 76 | “Most programs staggered education over time but the limited evidence showed no difference in new graduate nurse transition or satisfaction. New graduate nurse support was an important emphasis of all programs with preceptors the most common form of support and with beginning evidence showing quality vs quantity in preceptor support. Strengthening the quality of preceptor support was evident across studies with the bundling of concurrent strategies found to be helpful. Competency and confidence were found to increase over time for new graduate nurses in transition programs. Workplace environments influenced new graduate nurse transition and organizational commitment.”
Low (N = 6)
Alshawush, 2022^17^ | Scoping review; Search dates: Not reported; Included studies: 19 | “This review found that most transition programmes provide support for new graduate nurses when dealing with workplace violence, bullying and stress. Transition programmes varied in length, content and implementation. Preceptors’ support, educational sessions and safe work environments are the most beneficial elements of transition programmes for supporting new graduate nurses. Education sessions about resilience provide new graduate nurses with knowledge about how to deal and cope with stressful situations in the work environment. We found no studies that focused on nursing students.”
Asber, 2019^18^ | Integrative review; Search dates: conducted search Jan 2017; Included studies: 16 | “The 1-year retention was higher than the national average for new graduate nurses ranging from 74% to 100%.”
Chant, 2019^19^ | Integrative review; Search dates: 2007-?; Included studies: 18 | “Successful, sustainable nurse residency programs have a strong foundation with committed leadership to support transition; a structured program with defined outcomes to promote clinical competence, safe patient care, and professional development; and an evaluation process to guide continual improvement and meet organizational needs.”
Eckerson, 2018^20^ | Systematic review; Search dates: 2012–2017; Included studies: 12 | “Use of NRPs showed increased satisfaction and retention of new nurse graduates over a one-year period, leading to the conceptualization that this is a more effective method than traditional orientations for new nurse hires.”
Hampton, 2020^11^ | Integrative review; Search dates: Not reported; Included studies: 7 | “Despite the significance of the studies’ results that indicate interventions to ease the transition-to-practice experience are beneficial and can have a positive impact on areas such as job satisfaction and retention, overall findings from this integrative review suggest the need for greater standardization of concepts that should be evaluated and the instruments used to determine if new nurses are successfully transitioning into professional nursing.”
Wray, 2021^12^ | Rapid evidence assessment; Search dates: February 2018; Included studies: Unclear which includes mention residency | “Orientation and creating supportive environments were frequently reported as being effective in enhancing transition across a range of studies.”
Critically Low (N = 9)
Ackerson, 2018^21^ | Other; Search dates: 2006 through 5–9, 2016; Included studies: 26 | “Established programs with at least a 12-month time frame were slightly more effective at retention. However, retention was not sustained at year two.”
Aparicio, 2020^22^ | Other; Search dates: Unclear; Included studies: 6 | “Training (preceptorship and clinical supervision programmes) is effective in retaining NQNs, increasing satisfaction, improving skills and competency and staff engagement; however, more support for both preceptors/supervisors and NQNs is needed to maximise the success of these programmes in the future.”
Bakon, 2018^10^ | Integrative review; Search dates: 2005-June 2016; Included studies: 30 | “There are numerous transition programmes available yet there remains a lack of transparency regarding their aims/objectives, course content, support timeframe and the type of support provided. This inconsistency has resulted in a lack of clarity regarding efficacy or superiority of any one programme over another. Innovative multifaceted programs may assist in supporting the graduate registered nurse to transition effectively into the clinical environment.”
Cochran, 2017^23^ | Systematic review; Search dates: Jan 2011-Sept 2014; Included studies: 15 | “NRPs are a cost-effective method proven to reduce attrition rates of new nurses. The most effective programs are 12 months in duration and focus on mentor/preceptor support with structured didactic content to assist newly licensed registered nurses to develop successfully in their professional role.”
Hoover, 2020^24^ | Scoping review; Search dates: Sep 2019; Included studies: 69 | “Of the articles with sufficient data, they typically described small programs implemented in one facility (n = 23), with up to ten mentors (n = 13), with less than 50 mentees (n = 25), meeting at least once a month (n = 27), and lasting at least a year (n = 24). While over half of the studies (n = 36) described programs focused almost exclusively on clinical skills acquisition, many (n = 33) specified non-clinical professional development activities. Reflective practice featured to a varying extent in many articles (n = 29). Very few (n = 6) explicitly identified the theoretical basis of their programs.”
Kenny, 2021^13^ | Systematic review; Search dates: Not reported (included studies from January 1990 to April 2020); Included studies: 130 | “The majority of authors reported outcomes for the graduate or the graduate and service, with only one reporting outcomes for the patient or client.”
Letourneau, 2015^25^ | Integrative review; Search dates: 2006-July 2013; Included studies: 25 | “Specifically, this review revealed an emphasis on organizational priorities pertaining to adjustment of the newly licensed nurse to the work environment and role. Consequently, the focus was on nurse retention, quality of nurse performance, and confidence. To date, no research has examined whether there is a link between participation in an NRP and patient outcomes that are determined to be nursing sensitive (eg, pressure ulcers, falls, intravenous infiltrations).”
Tyndall, 2018^26^ | Integrative review; Search dates: 2010-June 2017; Included studies: 20 | “This integrated review affirms the lack of empirical evidence linking participation in transition programs with positive patient outcomes and increased patient safety. Self-reported competency improvement by NGNs is the most common variable used in studies asserting that transition programs improve patient safety.”
Van Camp, 2017^27^ | Systematic review; Search dates: 2004–2016; Included studies: 22 | “Results indicate increased retention rates for new graduates participating in residency programs and that residency participants experienced greater satisfaction with their orientation than those not participating in residency programs. Residency participants also perceived the residency as beneficial.”

Notes. AMSTAR2 categories of overall confidence in the results of the review:

High: Zero or 1 non-critical weakness: The systematic review provides an accurate and comprehensive summary of the results of the available studies that address the question of interest.

Moderate: More than 1 non-critical weakness^*^: The systematic review has more than 1 weakness, but no critical flaws. It may provide an accurate summary of the results of the available studies that were included in the review.

Low: One critical flaw with or without non-critical weaknesses: The review has a critical flaw and may not provide an accurate and comprehensive summary of the available studies that address the question of interest.

Critically low: More than 1 critical flaw with or without non-critical weaknesses: The review has more than 1 critical flaw and should not be relied on to provide an accurate and comprehensive summary of the available studies.

* Note: Multiple non-critical weaknesses may diminish confidence in the review and it may be appropriate to move the overall appraisal down from moderate to low confidence.

### Methodological Quality of Included Reviews

Table 3 Review Methodology and Confidence Categorization

| SysR | IR | ScR | REA | Other
High | 1
Moderate | 1 | 1 | 1
Low | 1 | 3 | 1 | 1
Critically low | 3 | 3 | 1 | | 2

Abbreviations. IR=integrative review; REA=rapid evidence assessment; ScR=scoping review; SysR=systematic review.

One systematic review^9^ met the standard of high confidence categorization (see Error! Reference source not found.). Three reviews, 1 systematic review,^16^ 1 scoping review,^15^ and 1 integrative review^8^ met the standard of moderate confidence. We heeded the AMSTAR2 guidance that multiple non-critical weaknesses may diminish confidence in the review, and it may be appropriate to move the overall appraisal down from moderate to low confidence; our categorizations reflect this. Six reviews—1 systematic review,^20^ 1 scoping review,^12^ 1 rapid evidence assessment,^12^ and 3 integrative reviews^11,18,19^—met the standard of low confidence. In addition, most reviews^10,13,21–27^ were categorized as critically low confidence.

The highest AMSTAR2 score among the 19 included reviews was 11 points out of a possible 13 points on the modified criteria; the lowest score was 3. The median and the mode scores were both 7 points, indicating that fewer than half of the quality criteria were met. In the preceding overview section, we discuss how these scores translated into overall confidence in a particular review. Here, we describe patterns in the individual criteria that were met or not met across included reviews. Figure 1 presents the frequency that included reviews met each AMSTAR2 criterion. Appendix F shows the detailed AMSTAR2 scores for each review. All 19 reviews stated a research question or documented inclusion criteria, whereas no review reported a funding source. At least 50% of the reviews stated a research question/inclusion criterion, including an explanation of publication type for inclusion; used a search strategy; described studies in adequate detail; explained heterogeneity; and reported conflicts of interest. All the other criteria were met by less than half of the scored reviews.

Figure 1 Included Reviews (N = 19) Meeting AMSTAR2 Criteria

## KEY QUESTION 1: ARE TRANSITION-TO-PRACTICE PROGRAMS FOR NEWLY GRADUATED, ENTRY-TO-PRACTICE REGISTERED NURSES EFFECTIVE FOR IMPROVING ORGANIZATIONAL, NURSE, AND PATIENT OUTCOMES?

### Reviews’ Coverage of Outcomes of Interest

The identified reviews discussed critical organizational-level outcomes and some nurse-level outcomes; however, patient-level outcomes were absent.

Due to a combination of methodological issues with the reviews themselves and/or with the literature they identified, no conclusions can be drawn with any level of certainty for specific outcomes.

### Best Available Evidence for Key Question 1

Because this was a broad, high-level systematic review of reviews, we prioritized reporting on the conclusions for outcomes included by the 2 reviews rated as having high or moderate confidence in the findings based on AMSTAR2 scoring and scoped to address our key questions.^8,9^ We also described findings from 6 reviews that were either rated as low confidence or had scoping differences but had salient information for this key question.^18,20,21,25,27,28^

The Rush and colleagues’ 2019 integrative review that was published in the International Journal of Nursing Studies had 3 missing criteria and was therefore rated as having moderate confidence.^8^ However, none of these missing criteria were critical or affected the transparency of reporting the results. In addition, the scope of the review, which was “to identify the best practices of formal new graduate nurse transition programs,” was exceptionally aligned with the scope of our review of reviews. The authors included the most comprehensive overlap of original research studies; however, they included single-component programs, which fell outside our definition of multi-component RNTTPs, and thus had other studies we did not include. They found that the quality of evidence, which was low to moderate overall, limited best-practice recommendations. They focused on 4 main categories of outcomes—competency and critical thinking, confidence, job satisfaction, and retention and turnover—while also describing data that were related to cost-benefit analyses. They found that the best quality evidence, which used a mix of methodological approaches, consistently connected RNTTPs with increased critical thinking, competency, and retention.

The systematic review by Brook and colleagues,^9^ also published in 2019 in the International Journal of Nursing Studies, was the only included review with a high confidence rating (ie, the review provided an accurate and comprehensive summary of the results of the available studies that addressed the question of interest).^9^ With 53 included studies, it aimed “to evaluate the characteristics of successful interventions to promote retention and reduce turnover of early career nurses.” Given its focus on quantitative analyses of retention and turnover, Brook and colleagues’ findings aligned with those of Rush and colleagues, stating that methodological issues limited the conclusions they could draw. They found indications that RNTTPs were associated with improved retention, but the composition of the program and its components also had some bearing on these improvements, which is discussed in more detail in key question 2. The authors identified future research areas, some of which have particular salience for this key question, most notably standardizing outcome measures across studies and increasing rigorous evaluations of RNTTPs’ cost effectiveness.

Four additional reviews, either published in 2019 or earlier, were rated as low or critically low confidence in the findings and had similar scopes that primarily focused on retention.^18,20,21,27^ These reviews also reached similar conclusions, but with fewer included studies and more methodological issues than those found in the Rush and Brook reviews.^8,9^

An additional 2 reviews^15,25^ included measurement-related findings that contributed to the discussion points raised by Brook and colleagues.^9^ A moderate confidence review published in 2021 concurred, stating that “there was no general agreement as to which outcomes were important, and many studies used poorly validated measures.”^15^ A critically low confidence review published previously in 2015 detailed measures in its analysis,^25^ which highlighted the Casey-Fink Graduate Nurse Experience Survey among a list of 6 other job satisfaction, performance, stress, and organizational commitment instruments. However, given the methodological issues and the 2015 publication date, this list was probably incomplete.

## KEY QUESTION 2: WHAT ARE THE CHARACTERISTICS OF EFFECTIVE TRANSITION-TO-PRACTICE PROGRAMS (EG, PROGRAM COMPONENTS, DURATION OF PROGRAM) FOR NEWLY GRADUATED, ENTRY-TO-PRACTICE RNS?

The 2 best-evidence reviews discussed in key question 1 contributed insights related to characteristics of RNTTPs.^8,9^ Each reviews’ results section was dedicated to “common features of transition programs”^8^ and “types of components”^9^ where a few key components were discussed. The 3 common features identified by Rush and colleagues^8^ included a defined resource person (eg, mentor, clinical coach, navigator), mentorship, and peer support opportunities. In addition, each review had separate sections dedicated to education and workplace environment. These align with Chant and colleagues’ model of nursing residency programs, notably themes under strong foundation and structured program (Figure 2).^19^

Brook and colleagues^9^ identified 5 unique program components, including preceptor, mentor, teaching/training, assessment (ie, evaluation of the program), and incentives components. These align with some of the model’s structured program and evaluation process themes (Figure 2).

Two additional reviews rated low and very low confidence that identified and discussed program components also contributed to insights related to RNTTP characteristics.^10,19^ The first of these, an integrative review rated low confidence, developed a model of RNTTP key components for sustainability (Figure 2).^19^ The authors did not report methods according to AMSTAR2, or in some cases they reported alternative, less rigorous approaches. Yet their approach was acceptable for developing their model, which aligned well with the 2 best quality reviews in terms of the components they described. Finally, the very low-quality integrative review included a list of 17 suggested elements for graduate transition programs, which overlapped with the model’s themes identified in Figure 2.

Figure 2 Chant and Colleagues’ Model of Nurse Residency Programs: Key Components for Sustainability^19^

All 4 reviews,^8–10,19^ in addition to other reviews mentioned in key question 1,^15,18,20,21,25,27,28^ discussed program length to some degree. However, given the methodological issues of both the identified reviews as well as their included literature, any signal about ideal program length was not grounded in empirical comparisons between programs of different lengths, and as such we were unable to rely on their interpretations beyond the findings reached by Rush and Brook and their colleagues.

Rush concluded that bundled programs (ie, programs with multiple components) can be helpful but the evidence for program length was inconclusive. However, orientations longer than 4 months, and ideally up to 9 months were suggested.^8^ Brook and colleagues agreed on both findings, suggesting that programs lasting 27–52 weeks with teaching, preceptor, and mentoring components appeared most promising.^9^

## REVIEWS NOT DISCUSSED IN KEY QUESTIONS

Nine reviews were precluded from further discussion in the preceding key questions sections.^11–13,16,17,22–24,26^ This was due to a combination of methodological issues and scope incompatibilities. Three systematic reviews,^16,22,24^ an integrative review,^11^ and a rapid evidence assessment^12^ included a mix of RNTTPs and programs that focused on mentorships, preceptorships, and/or orientations. Because the reviews’ findings were not separated by program type, we could not discern characteristics that were attributed to comprehensive RNTTPs versus single-component programs.

A scoping review describing transition programs’ impact on workplace violence, stress, and resilience did not separate new RN graduates from nursing students.^17^ One integrative review with critically low confidence focused on a conceptual model for patient safety.^26^ Because this review was not relevant to our key questions and it contained multiple serious methodological flaws, it was not included in the key question sections.

Two other reviews^13,23^ also had serious methodological issues and were not included in the key questions section. The first review did not present data for all included studies, nor did it identify them all.^13^ We were unable to rely on its conclusions, despite it being the largest review in our review, purporting to include 130 studies. The second review, a “literature review,” included a very limited description of methods but did not present sufficient information to support its conclusions.^23^

## CURRENT SYNTHESES’ COVERAGE OF THE EVIDENCE BASE

In this section, we present findings that empirically assess the identified reviews’ coverage, including both overlap between reviews as well as coverage across the original research evidence base more broadly.

### Overlap Between Existing Reviews

While many of the 19 identified reviews had similar objectives, the degree of overlap in original included literature was minimal (see Appendix G for full crosswalk). Of the 336 cumulative citations included in the 19 reviews, about two-thirds appeared only once, in a single review (N = 217, 65%). No study was included in every review; the most overlap for any single citation was inclusion in 10 reviews, which occurred twice.^29,30^

Coverage across the 336 studies was low for all included reviews. The largest review, which included 130 original research studies, did not specify all those citations: 88 of the 130 included studies were cited and were added to the crosswalk, which represented 26% (88/336) of all studies identified by prior reviews.^13^ The Rush and colleagues’ 2019 integrative review^8^ also included roughly a quarter of identified studies (24%, 79/336 studies), while all other reviews included less than 20% of the total identified literature from reviews (see Appendix G).

### Additional Findings from Indeoendent Searches

Given the indicators that no individual review consistently and fully represented the existing evidence base of original research studies, we conducted our own literature search, which identified 25 additional relevant original research studies that were not included in any of the prior syntheses.

We also screened all 336 studies identified by the reviews, and the majority did not meet our own inclusion criteria (N = 272, 81%). Because many reviews did not provide information about their screening and selection methodologies, it was unclear how these studies were included, or in what ways their inclusion process differed from our own. By our criteria, the 2 most common exclusion reasons were that studies only discussed a single component program (N = 98) or studies did not present data or analysis of outcomes from a specific program (N = 73).

### Summary of Coverage

There was no seminal study or set of studies that all review authors included, and the majority of literature identified by reviews was only included by a single review. No single review served as a reliable compilation of the evidence base, and all reviews included studies we would consider to be excludes by our eligibility criteria.