# METHODS

## REGISTRATION AND REVIEW

A preregistered protocol for this systematic review can be found on PROSPERO (CRD42023418830 (https://www.crd.york.ac.uk/prospero/display_record.php?RecordID=418830)). A draft version of this report was reviewed by external peer reviewers; their comments and author responses are located in Appendix A.

## KEY QUESTIONS AND ELIGIBILITY CRITERIA

This systematic review of reviews sought reviews that addressed the following key questions:

Key Question 1 | Are transition-to-practice programs for newly graduated, entry-to-practice RNs effective for improving organizational, nurse, and patient outcomes?
Key Question 2 | What are the characteristics of effective transition-to-practice programs (eg, program components, duration of program) for newly graduated, entry-to-practice RNs?

Review eligibility criteria are shown in the table below.

| Eligibility Criteria
Population | Newly graduated, entry-to-practice nurses (excluding nurse practitioners) in the first 12 months of employment following graduation and/or licensure for entry to practice.
Intervention | RNTTP or nurse residency programs specifically designed for newly graduated, entry-to-practice nurses to provide support or preceptorship during the first 12 months of employment following graduation and/or licensure for entry to practice. Programs must be 6 months or longer, or they were considered orientations rather than full RNTTPs. Programs must include some in-person component. Entirely remote or online/virtual programs were not included.
Comparator | Any comparator (eg, usual care, active comparator, historical controls) or no comparator.
Outcomes | Organizational outcomes (eg, retention/attrition, quality of care), nurse outcomes (eg, confidence, competence, practice-readiness, satisfaction), patient outcomes (eg, patient satisfaction, adverse events), components (eg, preceptorships, simulations), implementation characteristics (eg, duration, recruitment strategies, settings, utilization, uptake, barriers/facilitators, collaboration with academic partners).
Timing | Any
Setting | Any health care setting was eligible, as long as contents of the program were not so specialized to that setting that it resembled specialized training instead of a more general transition-to-practice program (eg, mental health-specific training in an exclusively mental health care setting); programs implemented in 2022 Organization for Economic Co-operation and Development member countries to approximate US health care delivery context.
Study Design | Syntheses including systematic reviews, integrative reviews, scoping reviews, and other reviews using a formal review methodology were included in the systematic review of reviews.

## SEARCHING AND SCREENING

To identify published evidence syntheses/reviews relevant to RNTTP, a research librarian conducted searches using a broad set of terms, including terms related to “transition to practice,” “new graduate nurse,” “transitional support,” and “Education, Nursing, Graduate,” with a systematic review delimiter in PubMed/MEDLINE and CINAHL Plus from 1/1/15–12/15/22. See Appendix B for the complete search strategy. The abstract and full text (FT) of each retrieved review were screened according to inclusion criteria.

## DATA ABSTRACTION AND QUALITY ASSESSMENT

Two reviewers independently abstracted data from each included review. Abstracted data included review type (ie, systematic review, integrative review, or other review using a formal review methodology), whether the article described context/factors contributing to the success or failure of the program (eg, setting, participants, components), excerpted relevant findings, the total number of studies included, and search dates (see Appendix C). Any discrepancies in data abstraction were resolved by group discussion.

Each published evidence synthesis was assessed using a modified version of the A MeaSurement Tool to Assess Systematic Reviews 2 (AMSTAR2) criteria.^14^ This 16-item tool is designed to assess the methodological quality of systematic reviews and meta-analyses and is considered the standard for this type of assessment. The tool includes domains such as descriptions of PICO (population, intervention, comparators, and outcomes) in both the inclusion criteria and results, PROSPERO registration, use of a comprehensive and timely literature search strategy, duplicate data abstraction, and analysis of the risk of bias. As some AMSTAR2 items concerned meta-analysis and did not apply to our set of reviews, we adapted the tool for this review, resulting in a 13-item tool. The full modified tool is available in Appendix D. We completed an assessment of published reviews using our modified tool in duplicate, with discrepancies resolved through group discussion.

AMSTAR2 is not intended to generate an overall numerical score, as high scores can mask critical weaknesses in domains, such as failing to assess the risk of bias.^14^ To that end, we critically appraised reviews and rated our confidence level in each review's results according to AMSTAR2 categorization guidance, as shown in Table 1.^14^ No reviews were excluded from our analysis based on AMSTAR2 scores.

Table 1 AMSTAR2 Guidance for Confidence Ratings and Criteria for Included Reviews

Rating | Criteria
High overall confidence | Review had 0 or 1 non-critical weakness and provided accurate and comprehensive summaries of the results available from included studies that addressed the research question of interest.
Moderate confidence | Review had 1 non-critical weakness but no critical flows and provided accurate summaries.
Low confidence | Review had a critical weakness and may not have provided accurate and comprehensive summaries.
Critically low confidence | Review had more than 1 critical weakness and should not be relied upon to provide accurate and comprehensive summaries.

## SYNTHESIS

### Main Synthesis Approach

We synthesized the findings of our systematic review of reviews using a narrative approach. We described the literature flow, identified reviews, and methodological quality findings. We narratively described the evidence for each key question.

### Analysis of Identified Reviews' Coverage of the Original Research Evidence Base

During our analysis of the published reviews we identified, we became aware that these reviews might not have fully incorporated all published original research in this area. Heterogeneity in the scope, quality, and methodologies of the reviews made efforts to summarize the full breadth of the literature unfeasible. To better understand and contextualize the reviews, we conducted a brief overview analysis of the review coverage described here.

Firstly, we assessed the degree of overlap of included publications across the included reviews. The review team hand-searched reference lists of included reviews to identify included publications. We then constructed a crosswalk table that mapped each included publication to the reviews that had included it.

Secondly, the research librarian conducted a second search in PubMed/MEDLINE and CINAHL for original research studies published from 1/1/10 to 12/21/22 using the same search terms as the previous review search but without the systematic review delimiter. We limited the search to published and indexed articles available in the English language.

Two team members worked independently and in duplicate to screen and abstract data from each identified original research study. Eligibility criteria were identical to the review screening process, except for publication type. Original research studies of any design were included, such as randomized trials, nonrandomized trials, controlled before-after studies, interrupted time-series studies or repeated measures studies, prospective and retrospective cohort studies, uncontrolled before and after studies (ie, pre-post study), and any study using qualitative methods. Conflicts between the 2 team members were resolved through discussion with a third team member. Each novel original research study categorized as eligible was added to the crosswalk table. Because these additional activities aimed to summarize the coverage of the reviews in the systematic review of reviews, we did not abstract study outcome data or evaluate studies for risks of bias.

Thirdly, we screened all publications included in prior reviews using the same process we used for the database search results and documented the publications included in prior reviews that met our eligibility criteria.

We characterized the degree to which reviews’ coverage overlapped with each other and with our database search for original research studies. We also described the literature flow of all original research studies through our screening process.