# BACKGROUND

In 2021, a national registered nurse (RN) staffing survey found that first-year hospital-based RNs had the highest turnover rate (32.8%) among all surveyed RNs.^1^ New graduate RNs often express that they experience many stages of internal conflict at the start of their nursing careers. A 2009 national survey of newly licensed RNs reported that they frequently felt stressed and insufficiently supported during the first 12 months of working in an acute care setting, despite having completed a rigorous educational program and clinical experience.^2^ This experience is referred to as “transition shock” or “reality shock.”^3^ This describes the initial and intense stage in transitioning from the role of student to graduate nurse, where they may feel anxious, insecure, and inadequate when facing the many challenges and expectations they encounter in a new work environment. Comprehensive transition-to-practice programs (RNTTPs) (also referred to as RNTTP residency programs) are intended to assist new graduate RNs with the “process of professional role socialization” and may help to improve retention among new RNs.^3^

Comprehensive RNTTPs are different from more narrowly focused programs (eg, mentorships) or those of shorter duration (eg, traditional orientations, preceptorships). Through accreditation, RNTTPs have continued to improve and advance, emphasizing evidence-based practice, quality improvement, professional development, and competency-based evaluations. Although multiple accrediting bodies exist, such as the American Nursing Credentialing Center, the Commission on Collegiate Nursing Education, and the Accreditation Commission for Education in Nursing, there is variation in program characteristics, such as program length, and how RNTTPs are implemented.^4^ This variability has created uncertainty among nurse leaders and administrators about the best practices for training new graduate RNs.^5^

When accreditation organizations were first established, the Institute of Medicine (IOM) published The Future of Nursing: Leading Change, Advancing Health^6^ in 2011, in which it recommended that the federal government, state boards of nursing, accreditation bodies, and health care organizations implement and support RNTTPs, through 1) collaborations among accreditation bodies to encourage RNs to complete RNTTPs, 2) actions of the Secretary of Health and Human Services to redirect funding from RN diploma programs to RNTTPs in rural and critical care access areas, 3) funding from Centers for Medicare and Medicaid Services and other health care organizations to develop and execute RNTTPs, and 4) health care organizations’ assessments of the effectiveness of their RNTTPs.^7^ The IOM also recommended that key outcomes, such as retention, expanding competencies, and patient outcomes, be included in RNTTP evaluations. Rigorously evaluating these outcomes would allow for comparisons between different RNTTP implementations, which would support nurse leaders and administrators to determine best practices.

“Healthcare organizations that offer nurse residency programs and foundations should evaluate the effectiveness of the residency programs in improving the retention of nurses, expanding competencies, and improving patient outcomes.”

-IOM Future of Nursing Report

Numerous reviews of RNTTPs have been conducted^8–10^ but often included a mix of RNTTPs, traditional orientations, and mentorship programs.^11–13^ In addition, the ever-growing number of reviews that looked directly at residency and RNTTPs need to be summarized. We conducted a systematic review of published evidence syntheses on RNTTPs to support the Office of Nursing Services (ONS) as they plan for the continued sustainment, evolution, and evaluation of VA’s national RNTTP implementation.