# APPENDIX G RNTTP CROSSWALK

Please see Excel file for crosswalk (https://vaww.hsrd.research.va.gov/publications/esp/Appendix-G-RNTTP-Crosswalk.xlsx).