# APPENDIX F AMSTAR2 SCORES

Author, Year | Stated Research Question/Inclusion Criteria | Protocol or PROSPERO | Explanation of Study Design for Inclusion | Use Search Strategy | Selected Studies in Duplicate | Extracted Data in Duplicate | Provided List of Excluded Studies | Described Studies in Adequate Detail | Assessed Risk of Bias | Reported Funding Source for Included Studies | Accounted for Risk of Bias in Interpretation | Explained Heterogeneity | Reported Conflict of Interest
Reviews Meeting Criteria | 19 | 4 | 15 | 17 | 7 | 4 | 6 | 16 | 8 | 0 | 9 | 13 | 16
% | 100% | 21% | 79% | 89% | 37% | 21% | 32% | 84% | 42% | 0% | 47% | 68% | 84%
High^a,b^ (n=1)
Brook, 2019^9^ | X | X | X | X | X | | X | X | X | | X | X | X
Moderate (n=3)
Aldosari, 2021^15^ | X | | X | X | X | | | X | | | X | X | X
Ke, 2017^16^ | X | | X | X | X | X | | X | X | | X | X | X
Rush, 2019^8^ | X | | X | X | X | | | X | X | | X | X | X
Low (n=6)
Alshawush, 2022^17^ | X | | X | X | X | X | | X | | | | | X
Asber, 2019^18^ | X | | X | X | | | | X | X | | | X | X
Chant, 2019^19^ | X | | X | X | | | | X | X | | | X | X
Eckerson, 2018^20^ | X | | X | X | | | | X | X | | X | X | X
Hampton, 2020^11^ | X | | X | X | | | | X | | | X | X | X
Wray, 2021^12^ | X | X | X | X | X | | X | | X | | X | X | X
Critically Low (n=9)
Ackerson, 2018^21^ | X | | | X | | | | X | | | | X | X
Aparicio, 2020^22^ | X | X | | X | | X | X | X | X | | X | | X
Bakon, 2018^10^ | X | | | X | | | | X | | | | | X
Cochran, 2017^23^ | X | | X | | | | | X
Hoover, 2020^24^ | X | | X | X | | | X | | | | | X | X
Kenny, 2021^13^ | X | X | X | X | X | X | X
Letourneau, 2015^25^ | X | | | | | | | X | | | | X
Tyndall, 2018^26^ | X | | X | X | | | X | X | | | | | X
Van Camp, 2017^27^ | X | | X | X | | | | X | | | X | X | X

Notes.

a Partial yes was counted as “yes” and given 1 point; unclear/can’t answer was counted as “no” and not given 1 point.

b Rating overall confidence in the results of the review:

High: Zero or 1 non-critical weakness: The systematic review provides an accurate and comprehensive summary of the results of the available studies that address the question of interest.

Moderate: More than 1 non-critical weakness^*^: The systematic review has more than 1 weakness, but no critical flaws. It may provide an accurate summary of the results of the available studies that were included in the review.

Low: One critical flaw with or without non-critical weaknesses: The review has a critical flaw and may not provide an accurate and comprehensive summary of the available studies that address the question of interest.

Critically low: More than 1 critical flaw with or without non-critical weaknesses: The review has more than 1 critical flaw and should not be relied on to provide an accurate and comprehensive summary of the available studies.

* Note: Multiple non-critical weaknesses may diminish confidence in the review, and it may be appropriate to move the overall appraisal down from moderate to low confidence.