# APPENDIX E STUDIES EXCLUDED DURING FULL-TEXT SCREENING

Citation | Exclude Reason
Abel, S.E. and H. Carter-Templeton, Implementing a Transition-to-Practice Program for Novice Clinical Nurse Specialists: A Pilot Project. Clinical Nurse Specialist: The Journal for Advanced Nursing Practice, 2020. 34(4): p. 162–169. | Ineligible Population
AbuAlRub, R. F. and M. G. Abu Alhaija'a (2019). "Perceived benefits and barriers of implementing nursing residency programs in Jordan." Int Nurs Rev 66(1): 43–51.29498034 | Ineligible Setting
Adamack, M. and K.L. Rush, Disparities in new graduate transition from multiple stakeholder perspectives. Nurs Leadersh (Tor Ont), 2014. 27(3): p. 16–28. | Unable to Locate FT
Al-Dossary, R.N., P. Kitsantas, and P.J. Maddox, Clinical decision-making among new graduate nurses attending residency programs in Saudi Arabia. Appl Nurs Res, 2016. 29: p. 25–30.26856484 | Ineligible Setting
Allanson, A.M. and P. Fulbrook, Preparation of nurses for novice entry to perioperative practice: evaluation of a short education program.. ACORN: The Journal of Perioperative Nursing in Australia, 2010. 23(2): p. 14–16. | Ineligible Population
Allen, S.R., P. Fiorini, and M. Dickey, A streamlined clinical advancement program improves RN participation and retention. J Nurs Adm, 2010. 40(7–8): p. 316–22.20661061 | Ineligible Population
Anderson, G., Hair, C., & Todero, C. (2012). Nurse residency programs: An evidence-based review of theory, process and outcomes. Journal of Professional Nursing, 28(4), 203–212.22818190 | Ineligible Setting
Beaty, J., , The Ontario new graduate nursing initiative: an exploratory process evaluation. Healthc Policy, 2009. 4(4): p. 43–50.20436806 | Ineligible Intervention
Blanzola, C., R. Lindeman, and M.L. King, Nurse internship pathway to clinical comfort, confidence, and competency. J Nurses Staff Dev, 2004. 20(1): p. 27–37.15076126 | Ineligible Intervention
Bolden, L., , The use of reflective practice in new graduate registered nurses residency program. Nurs Adm Q, 2011. 35(2): p. 134–9.21403487 | Ineligible Publication Type
Bratt, M.M., Retaining the next generation of nurses: the Wisconsin nurse residency program provides a continuum of support. J Contin Educ Nurs, 2009. 40(9): p. 416–25.19754029 | Ineligible Publication Type
Burr, S.G. and G. Malagon-Maldonado, Implementation of a Nurse Residency Program in a Women and Newborn's Specialty Hospital: A Magical Transformation. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing, 2014. 43(Supp 1): p. S57–S57. | Ineligible Publication Type
Cadmus, E., , Academic practice partnership: transitions into practice for new nurses, part 2. Nurs Manage, 2014. 45(10): p. 12–4. | Ineligible Publication Type
Cadmus, E., , Academic practice partnership: transitions into practice for new nurses. Nurs Manage, 2014. 45(9): p. 10–2. | Ineligible Publication Type
Cantrell M.A., B.A.M., The impact of a nurse externship program on the transition process from graduate to registered nurse.. J. Nurses Staff. Dev., 2005. 6: p. 21. | Ineligible Intervention
Cleary, M., S. Matheson, and B. Happell, Evaluation of a transition to practice programme for mental health nursing. J Adv Nurs, 2009. 65(4): p. 844–50.19243464 | Ineligible Intervention
Dimino, K., , Exploring the Impact of a Dedicated Education Unit on New Graduate Nurses' Transition to Practice. J Nurses Prof Dev, 2020. 36(3): p. 121–128.32149894 | Ineligible Population
Edwards, D., , A systematic review of the effectiveness of strategies and interventions to improve the transition from student to newly qualified nurse. Int J Nurs Stud, 2015. 52(7): p. 1254–68.26001854 | Ineligible Publication Type
Failla, K.R., , Psychometric Testing of a Nurse Residency Program Stakeholder Evaluation Survey. Journal for Nurses in Professional Development, 2021. 37(6): p. 353–357.34723839 | Ineligible Intervention
Faron, S. and D. Poeltler, Growing our own: inspiring growth and increasing retention through mentoring. Nurs Womens Health, 2007. 11(2): p. 139–43.17883795 | Ineligible Population
Fielden, J.M., Managing the transition of Saudi new graduate nurses into clinical practice in the Kingdom of Saudi Arabia. J Nurs Manag, 2012. 20(1): p. 28–37.22229898 | Ineligible Publication Type
Flexibility in Competency-Based Workplace Transition Programs: An Exploratory Study of Community Child and Family Health Nursing. Journal of Continuing Education in Nursing, 2013. 44(3): p. 129–136.23421350 | Ineligible Intervention
Forde-Johnston, C., Developing and evaluating a foundation preceptorship programme for newly qualified nurses. Nurs Stand, 2017. 31(42): p. 42–52. | Ineligible Intervention
Fowler, S.B., P.R. Johnson, and J. Lewis, New Graduate Nurses' Art of Nursing Stories at Graduation From a Transition to Practice Program. Clin Nurse Spec, 2021. 35(2): p. 101–102.33534254 | Ineligible Publication Type
Gallagher, K.A. and A. Ricords, A Statewide Nurse Residency Model: Impacting the Transition of Newly Licensed Nurses. J Nurses Prof Dev, 2021. 37(3): p. 165–167.33961362 | Ineligible Publication Type
Garrison, E., Orienting the New Graduate Nurse to Floating: Ideas to Ease the Transition. J Nurses Prof Dev, 2018. 34(2): p. 112–115.29481470 | Ineligible Intervention
Haggerty, C., , 'We need to grow our own': an evaluation of nurse entry to practice programmes. Whitireia Nursing Journal, 2010(17): p. 16–20. | Ineligible Publication Type
Hall, S., , Transition to Practice: Onboarding Components for Establishing and Sustaining Healthy Work Environments. AACN Advanced Critical Care, 2019. 30(4): p. 416–420.31951662 | Ineligible Publication Type
Hall, S., S. Brady, and C. Altobar, Developing Organizational Capacity Through an Innovative Transition RN Fellowship. Journal for Nurses in Professional Development, 2020. 36(3): p. 170–173.32355059 | Ineligible Population
Hampton, K.B., S.C. Smeltzer, and J.G. Ross, Nonclinical Transition-to-Practice Courses: A Review of Course Content. Nurse Educ, 2021. 46(1): p. 54–58.32195765 | Ineligible Intervention
Healy, A., , An Evaluation of Traditional Versus Virtual Nurse Residency Programs on New Graduate Nurses' Perceptions of Preparedness to Provide Safe Patient Care. J Nurses Prof Dev, 2022. 38(4): p. 233–241.35776931 | Ineligible Intervention
Herdrich, B. and A. Lindsay, Nurse residency programs: Redesigning the transition into practice. J Nurses Staff Dev, 2006. 22(2): p. 55–62; quiz 63–4.16603901 | Ineligible Publication Type
Hillman, L. and R.R. Foster, The impact of a nursing transitions programme on retention and cost savings. J Nurs Manag, 2011. 19(1): p. 50–6.21223405 | Ineligible Intervention
Hooper, B. L. (2014). Using case studies and videotaped vignettes to facilitate the development of critical thinking skills in new graduate nurses. Journal for nurses in professional development, 30(2), 87–91.24658041 | Ineligible Intervention
Hosking, J., , Evidence Into Practice: Leading New Graduate Nurses to Evidence-Based Practice Through a Nurse Residency Program. J Perianesth Nurs, 2016. 31(3): p. 260–5.27235964 | Ineligible Intervention
Hu, F., , A transition programme to enhance ICU new graduate nurses' professional identity and intention to remain employed: A pre- and postevaluation. Nurs Open, 2022. | Ineligible Intervention
Hunsberger, M., A. Baumann, and M. Crea-Arsenio, The road to providing quality care: orientation and mentorship for new graduate nurses. Can J Nurs Res, 2013. 45(4): p. 72–87.24617281 | Ineligible Intervention
Innovation During Orientation: How Does Rhetoric Drive New Graduate Nurse Performance? Corrigendum. J Nurses Prof Dev, 2021. 37(2): p. E4.33630526 | Ineligible Intervention
Johansson, A., M. Berglund, and A. Kjellsdotter, Clinical Nursing Introduction Program for new graduate nurses in Sweden: study protocol for a prospective longitudinal cohort study. BMJ Open, 2021. 11(2): p. e042385. | Ineligible Publication Type
Jones, D. and N. West, Community-based transition programs: California's answer to the new-graduate hiring crisis. Journal of Nursing Regulation, 2010. 1(2): p. 14–17. | Ineligible Publication Type
Justus, P.D. and S.J. Appel, Simulation With Advanced Care Providers in a Nurse Residency Program. J Nurses Prof Dev, 2018. 34(4): p. 180–184.29975309 | Ineligible Intervention
Karen, L. and M. Donnya, New Graduate Transition Program Appraisal: Are We Bridging the Gap? Communicating Nursing Research, 2013. 46: p. 530–530. | Unable to Locate FT
Kennedy, M.S., Retaining Nurses in the Workplace. AJN American Journal of Nursing, 2013. 113(11): p. 7–7. | Ineligible Publication Type
Kram, S.L. and J. Wilson, Nurse residency program attracts and retains novice nurses. Nursing, 2016. 46(2): p. 15–6. | Ineligible Publication Type
Lambson, K., , BUILDING AN INNOVATIVE AND INDIVIDUALIZED NEW GRADUATE RN PROGRAM TO BOLSTER OUTPATIENT ONCOLOGY NURSING PRACTICE...47th Annual Oncology Nursing Society Congress, April 27–May 1, 2022, Anaheim, CA. Oncology Nursing Forum, 2022. 49(2): p. 21–22.34914677 | Ineligible Intervention
Larsen, R., , Development of a new graduate public health nurse residency program using the core competencies of public health nursing. Public Health Nurs, 2018. 35(6): p. 606–612.29947429 | Ineligible Intervention
Lesher, B.B., , New Graduate RN Perinatal Internship. J Contin Educ Nurs, 2021. 52(1): p. 47–52.33373008 | Ineligible Intervention
Letourneau, R.M. and K.H. Fater, Nurse Residency Programs: An integrative Review of the Literature. Nurs Educ Perspect, 2015. 36(2): p. 96–101.29194133 | Ineligible Publication Type
Lin, L.Y., & Tsai, S. F., Comparison of the effectiveness between two nursing competency training programs of newly employed nurse. VGH Nursing, 2010. 27: p. 231–239. | Unable to Locate FT
Lindfors, K. and K. Junttila, The effectiveness of orientation programs on professional competence and organizational commitment of newly graduated nurses in specialized health care: a systematic review protocol. JBI Database of Systematic Reviews & Implementation Reports, 2014. 12(5): p. 2–14. | Ineligible Publication Type
Lynn, M., UHC/AACN nurse residency program: 2014 outcomes report. 2014. | Unable to Locate FT
Lysaght Hurley, S., , Bridging the Gap: A Hospice Nurse Residency Program. J Contin Educ Nurs, 2020. 51(8): p. 371–376.32722815 | Ineligible Population
Manzano, W., R.R. Rivera, and R. Sullivan, What We Have Learned from a Model Nurse Residency Program: Ideas for Linking Service and Education. Nursing Education Perspectives (National League for Nursing), 2013. 34(6): p. 371–371. | Ineligible Publication Type
Maresca, R., , Lessons Learned: Accessing the Voice of Nurses to Improve a Novice Nurse Program. J Nurses Prof Dev, 2015. 31(4): p. 218–24.26200302 | Ineligible Intervention
Maryniak, K., Enhancing the New Nurse Experience: Creation of a New Employee Training Unit. Nursing Economic$, 2017. 35(6): p. 322–326. | Ineligible Publication Type
Mauro, A.M., L.A. Escallier, and M.G. Rosario-Sim, New Careers in Nursing Scholar Alumni Toolkit: Development of an Innovative Resource for Transition to Practice. J Prof Nurs, 2016. 32(5s): p. S59–s62.27659758 | Ineligible Publication Type
Maxwell, K.L., The implementation of the UHC/AACN new graduate nurse residency program in a community hospital. Nurs Clin North Am, 2011. 46(1): p. 27–33.21320658 | Ineligible Publication Type
McInnes, S., , Experiences of registered nurses in a general practice-based new graduate program: a qualitative study. Aust J Prim Health, 2019. 25(4): p. 366–373.31550436 | Ineligible Intervention
Mellor, P., , A Critical Review of Transition-to-Professional-Practice Programs: Applying a Standard Model of Evaluation. Journal of Nursing Regulation, 2017. 8(2): p. 23–30. | Ineligible Publication Type
Meyer, D., Transition to Practice. Teaching & Learning in Nursing, 2019. 14(4): p. 314–314. | Ineligible Publication Type
Missland, J. and H. Huizinga, DEVELOPMENT OF AN ONCOLOGY SPECIFIC NURSE RESIDENCY PROGRAM...47th Annual Oncology Nursing Society Congress, April 27-May 1, 2022, Anaheim, CA. Oncology Nursing Forum, 2022. 49(2): p. E84–E85. | Ineligible Publication Type
Morphet, J., , Transition to Specialty Practice Program characteristics and professional development outcomes. Nurse Educ Today, 2016. 44: p. 109–15. | Ineligible Population
Morphet, J., McKenna, L., Considine, J., The career development year: responding to the emergency nursing shortage in Australia.. Australasian Emerg. Nurs., 2008. 11: p. 32–38. | Ineligible Population
Morris, K., N. Morris, and S. Kinney, Nurses New to Paediatric Intensive Care: Knowledge Outcomes of a 12-week Transition to Specialty Practice Program...43rd Australian and New Zealand Annual Specific Meeting on Intensive Care and 24th Annual Pediatric and Neonatal Intensive Care Conference, 11–13 October 2018, Australia. Australian Critical Care, 2019. 32: p. S5–S5. | Ineligible Intervention
Morton, L., Halse, J., Cox, D., Preceptorship Framework. 2017, NHS England. | Ineligible Intervention
NETP programme attracts nurses from the community. Kai Tiaki Nursing New Zealand, 2011. 17(5): p. 7–7. | Ineligible Publication Type
Olson, R.K., , Nursing student residency program: a model for a seamless transition from nursing student to RN. J Nurs Adm, 2001. 31(1): p. 40–8.11198841 | Ineligible Population
Oosterbroek, T.A., Yonge, O., Myrick, F., Rural nursing preceptorship: an integrative review. Online J. Rural Nurs. Health Care 2017. 17(1): p. 23–51. | Ineligible Intervention
Orsini, C.H., A nurse transition program for orthopaedics: creating a new culture for nurturing graduate nurses. Orthop Nurs, 2005. 24(4): p. 240–6; quiz 247–8.16056167 | Ineligible Intervention
Parsh, B. and E. Taylor, CLINICAL QUERIES. Benefits of residency programs for new grads. Nursing, 2013. 43(12): p. 64–64. | Ineligible Publication Type
Peltzer, J.N., , The Kansas Nurse Leader Residency Program: Building Nurses' Capacity to Lead Change. J Nurses Prof Dev, 2018. 34(5): p. E1–e8. | Ineligible Publication Type
Pertiwi, R.I. and R.T.S. Hariyati, Effective orientation programs for new graduate nurses: A systematic review. Enfermería Clínica, 2019. 29: p. 612–618. | Ineligible Publication Type
Pillai, S., , Evaluation of a Nurse Residency Program. J Nurses Prof Dev, 2018. 34(6): p. E23–e28.30379776 | Ineligible Intervention
Pizzingrilli B, C.D., Implementation and evaluation of a mental health nursing residency program.. J Nurs Ed Pract., 2015. 5(1): p. 76–84. | Ineligible Intervention
Porter, V., C. Ham, and L. Grealish, Transition to Practice Program: A New Direction for Recruiting and Retaining Enrolled Nurses in Mental Health. J Nurses Prof Dev, 2016. 32(6): p. 299–305.27846080 | Ineligible Intervention
Ready, R.W., , The Transition of Newly Licensed Nurses Into the Workforce: Implementing a Designated Transition Unit in a Community Hospital Healthcare System. Nurse Leader, 2012. 10(4): p. 26–30. | Ineligible Intervention
Rhéaume, A., L. Clément, and N. Lebel, Understanding intention to leave amongst new graduate Canadian nurses: a repeated cross sectional survey. Int J Nurs Stud, 2011. 48(4): p. 490–500.20863497 | Ineligible Intervention
Rivera, E.K., H.J. Shedenhelm, and A.L. Gibbs, Improving Orientation Outcomes: Implementation of Phased Orientation Process in an Intermediate Special Care Nursery. J Nurses Prof Dev, 2015. 31(5): p. 258–63.26381335 | Ineligible Intervention
Roche, J., D. Schoen, and A. Kruzel, Human Patient Simulation Versus Written Case Studies for New Graduate Nurses in Nursing Orientation: A Pilot Study. Clinical Simulation in Nursing, 2013. 9(6): p. e199–205. | Ineligible Intervention
Saver, C., 12-week program prepares new nurses for the OR. OR Manager, 2017. 33(3): p. 1, 10–3. | Unable to Locate FT
Shinners, J., L. Africa and D. Meyer (2021). "The Nursing Professional Development Role in Fostering Professional Development, Leadership, and Academic Progression for New Graduate Registered Nurses." J Nurses Prof Dev 37(5): 260–267.34101711 | Ineligible population
Shope, B., , The Nurse Resident in the Pacu: Designing and Implementing a Program to Support the Transition of New Graduate Nurses into a Post Anesthesia Care Unit (PACU). Journal of PeriAnesthesia Nursing, 2016. 31(4): p. e41–e41. | Ineligible Publication Type
Smyth, W., P. Pianta, and R. Perkins, New Nurses' Positive Evaluation of Transition-to-Practice Programs. J Contin Educ Nurs, 2018. 49(11): p. 500–506.30376140 | Unable to Locate FT
Snow, T., Call for mandatory preceptorship programme for all new nurses. Nurs Stand, 2013. 27(19): p. 12–3. | Ineligible Intervention
Spector, N., , Transition to Practice in Nonhospital Settings. Journal of Nursing Regulation, 2015. 6(1): p. 4–13. | Ineligible Intervention
Teferra, A., Mengistu, D., Knowledge and attitude towards nursing clinical preceptorship among Ethiopian nurse educators: an institution-based cross-sectional study. International Journal of Africa Nursing Sciences., 2017. 7: p. 82–88. | Ineligible Intervention
The Effectiveness of Simulation Use in Transition to Practice Nurse Residency Programs: A Review of Literature from 2009–2018. Journal for Nurses in Professional Development, 2021. 37(6): p. E44–E45.34723844 | Ineligible Intervention
Torres, D.A., , Best Fit Orientation: An Innovative Strategy to Onboard Newly Licensed Nurses. J Nurses Prof Dev, 2022. 38(6): p. 350–359.34334735 | Ineligible Intervention
Trepanier, S., , Nursing Academic–Practice Partnership: The Effectiveness of Implementing an Early Residency Program for Nursing Students. Nurse Leader, 2017. 15(1): p. 35–39. | Ineligible Population
Tseng, M.Y. and S.L. Hwang, "SURVIVAL" intervention program effects on student nurses' transition to staff nurses: A quasi-experimental study. Nurse Educ Pract, 2021. 56: p. 103184.34492586 | Ineligible Intervention
Tuckett, A., R. Eley, and L. Ng, Transition to practice programs: What Australian and New Zealand nursing and midwifery graduates said. A Graduate eCohort Sub-Study. Collegian, 2017. 24(2): p. 101–108. | Ineligible Population
Valdes, E.G., M.C. Sembar, and F. Sadler, Onboarding New Graduate Nurses Using Assessment-Driven Personalized Learning to Improve Knowledge, Critical Thinking, and Nurse Satisfaction. J Nurses Prof Dev, 2021. | Ineligible Intervention
Varner, K.D. and R.A. Leeds, Transition within a graduate nurse residency program. J Contin Educ Nurs, 2012. 43(11): p. 491–9; quiz 500– 1.23061408 | Ineligible Publication Type
Vergara, J.Y., Implementation of a mentorship program to increase staff satisfaction and retention in critical care. Nurse Lead., 2017: p. 207–217. | Ineligible Intervention
Wallace, J., , Economic aspects of community-based academic-practice transition programs for unemployed new nursing graduates. J Nurses Prof Dev, 2014. 30(5): p. 237–41.25237915 | Ineligible Intervention
Warren, J.I., S. Perkins, and M.A. Greene, Advancing New Nurse Graduate Education Through Implementation of Statewide, Standardized Nurse Residency Programs. Journal of Nursing Regulation, 2018. 8(4): p. 14–21. | Ineligible Publication Type
Weathers, N.M. and L.A. Forneris, Innovation in Nurse Residency: Blazing a Trail With Online Technology. Nurs Educ Perspect, 2020. 41(5): p. 312–314.32769846 | Ineligible Intervention
Welding, N.M., Creating a nursing residency: decrease turnover and increase clinical competence. Medsurg Nurs, 2011. 20(1): p. 37–40.21446293 | Ineligible Publication Type
Weller-Newton, J.M., , Transition to Practice Programs in Nursing: A Rapid Review. Journal of Continuing Education in Nursing, 2022. 53(10): p. 442–450.36178755 | Ineligible Publication Type
Wilson, T., N. Weathers, and L. Forneris, Evaluation of Outcomes From an Online Nurse Residency Program. J Nurs Adm, 2018. 48(10): p. 495–501.30239446 | Ineligible Intervention
Windey, M., , Floating to the Top: Transition to Practice Program. Journal for Nurses in Professional Development, 2020. 36(2): p. 104–107.32106209 | Ineligible Publication Type
Windey, M., J. Houle, and D. Fleming, Legal Aspects of Transition to Practice Programs. Journal for Nurses in Professional Development, 2019. 35(4): p. 225–227.31268933 | Ineligible Intervention
Windey, M., M. Mullen, and S.O. Seiler, Escaping the Confines of Traditional Instruction: The Use of the Escape Room in a Transition to Practice Program. Journal for Nurses in Professional Development, 2019. 35(6): p. 354–356.31688485 | Ineligible Intervention
Young, M., A New Vision for Transition to Practice Programs. Journal for Nurses in Professional Development, 2021. 37(5): p. 301–304.34473455 | Ineligible Publication Type
Zhang, Y., , The effectiveness and implementation of mentoring program for newly graduated nurses: A systematic review. Nurse Educ Today, 2016. 37: p. 136–44.26725949 | Ineligible Publication Type