# APPENDIX D AMSTAR2 FORM

1. Did the research questions and inclusion criteria for the review include the components of PICO?
  PICO = population, intervention, comparator group, outcome
  ○ Yes
  ○ No
  ○ Unclear/can't answer
2. Did the report of the review contain an explicit statement that the review methods were established prior to the conduct of the review and did the report justify any significant deviations from the protocol?
  For Yes: Authors state that they had a written protocol or guide that included ALL the following—review question(s), a search strategy, inclusion/exclusion criteria, a risk of bias assessment, a meta-analysis/synthesis plan, if appropriate, a plan for investigating causes of heterogeneity, a plan for investigating causes of heterogeneity, and protocol should be registered.
  For Partial Yes: Authors state that they had a written protocol or guide that included ALL the following--review question(s), a search strategy, inclusion/exclusion criteria, a risk of bias assessment
  ○ Yes
  ○ Partial Yes
  ○ No
  ○ Unclear/can't answer
3. Did the review authors explain their selection of the study designs for inclusion in the review?
  For Yes: the review should satisfy ONE of the following-- Explanation for including only RCTs, OR Explanation for including only NRSI, OR Explanation for including both RCTs and NRSI
  ○ Yes
  ○ No
  ○ Unclear/can't answer
4. Did the review authors use a comprehensive literature search strategy?
  For Yes, should have: searched at least 2 databases relevant to research question (one of the databases MUST BE CINAHL), provided key word and/or search strategy, and conducted search within 24 months of completion of the review, AND could have more than one of these: justified publication restrictions(eg language), searched the reference lists / bibliographies of included studies, searched trial/study registries, included/consulted content experts in the field, where relevant, searched for grey literature.
  For Partial Yes (all of the following): searched at least 2 databases (relevant to research question), provided key word and/or search strategy, justified publication restrictions (eg language)
  ○ Yes
  ○ Partial Yes
  ○ No
  ○ Unclear/can't answer
5. Did the review authors perform study selection in duplicate?
  For Yes, either ONE of the following: at least two reviewers independently agreed on selection of eligible studies and achieved consensus on which studies to include OR two reviewers selected a sample of eligible studies and achieved good agreement (at least 80 percent), with the remainder selected by one reviewer
  ○ Yes
  ○ No
  ○ Unclear/can't answer
6. Did the review authors perform data extraction in duplicate?
  For Yes, either ONE of the following: at least two reviewers achieved consensus on which data to extract from included studies, OR two reviewers extracted data from a sample of eligible studies and achieved good agreement (at least 80 percent), with the remainder extracted by one reviewer, OR data was extracted by one reviewer and agreed upon by another reviewer.
  ○ Yes
  ○ No
  ○ Unclear/can’t answer
7. Did the review authors provide a list of excluded studies and justify the exclusions?
  For Yes, must have: provided a list of all potentially relevant studies that were read in full-text form but excluded from the review, justified the exclusion from the review of each potentially relevant study
  For Partial Yes: provided a list of all potentially relevant studies that were read in full-text form but excluded from the review
  ○ Yes
  ○ Partial Yes
  ○ No
  ○ Unclear/can't answer
8. Did the review authors describe the included studies in adequate detail?
  In an aggregated form such as a table, data from the original studies should be provided on the participants, interventions and outcomes. The ranges of characteristics in all the studies analyzed eg age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases should be reported.
  ○ Yes
  ○ No
  ○ Unclear/can't answer
9. Did the review authors use a satisfactory technique for assessing the risk of bias (RoB) or quality in individual studies that were included in the review?
  For Yes, must have assessed RoB with a formal tool that addresses factors including: allocation sequence that was not truly random, and selection of the reported result from among multiple measurements or analyses of a specified outcome, unconcealed allocation, lack of blinding of patients and assessors when assessing outcomes (unnecessary for objective outcomes such as all-cause mortality) for RCTS and methods used to ascertain exposures and outcomes, and selection of the reported result from among multiple measurements or analyses of a specified outcome, from confounding, and from selection bias for NRSI (Non-Randomized Study of Intervention) where appropriate. Must also present data for all included studies (can be summary score only but must be able to tell each includes quality score)
  For Partial Yes: used appropriate quality assessment or risk of bias assessment for all included studies. Must specify tool and/or criteria used AND present data for all included studies (can be summary score only but must be able to tell each includes quality score)
  ○ Yes
  ○ Partial Yes
  ○ No
  ○ Unclear/can't answer
10. Did the review authors report on the sources of funding for the studies included in the review?
  For Yes: Must have reported on the sources of funding for individual studies included in the review. Note: Reporting that the reviewers looked for this information, but it was not reported by study authors also qualifies.
  ○ Yes
  ○ No
  ○ Unclear/can't answer
11. Did the review authors account for RoB in individual studies when interpreting/ discussing the results of the review?
  For Yes: included only low risk of bias RCTs OR, if RCTs with moderate or high RoB, or NRSI were included the review provided a discussion of the likely impact of RoB on the results.
  ○ Yes
  ○ No
  ○ Unclear/can't answer
12. Did the review authors provide a satisfactory explanation for, and discussion of, any heterogeneity observed in the results of the review?
  For Yes: There was no significant heterogeneity in the results OR if heterogeneity was present the authors performed an investigation of sources of any heterogeneity in the results and discussed the impact of this on the results of the review.
  ○ Yes
  ○ No
  ○ Unclear/can't answer
13. Did the review authors report any potential sources of conflict of interest, including any funding they received for conducting the review?
  For Yes: The authors reported no competing interests OR the authors described their funding sources and how they managed potential conflicts of interest
  ○ Yes
  ○ No
  ○ Unclear/can't answer