# APPENDIX C FULL TEXT ABSTRACTION FORM

Full-Text Abstraction Form and Criteria Used in Quality Assessment

[underlined: Full-Text Abstraction Form]

1. Is the subject of this publication a transition to practice program(s) for early career nurses?
  a. Yes, CONTINUE
  b. No, no specific transition to practice program described - STOP SCREENING
  c. No, Ineligible Population - STOP SCREENING
  d. No, NPs or other clinical professionals - STOP SCREENING
  e. No, only one component of a specific transition to practice program specified (eg. simulation, orientation, preceptorship, mentorship, long-term care, other), STOP SCREENING (describe):
  f. Unclear/To discuss (explain here:)
2. Does this publication present data/results from an evaluation of an RNTTP?
  a. Yes, quantitative data and statistical analysis from a SINGLE site
  b. Yes, quantitative data and statistical analysis from MORE THAN ONE site
  c. Yes, qualitative data and analysis from a SINGLE site
  d. Yes, qualitative data and analysis from MORE THAN ONE site
  e. Yes, mixed methods from a SINGLE site
  f. Yes, mixed methods from MORE THAN ONE site
  g. No, commentary/editorial/no data analysis presented - STOP SCREENING
  h. Unclear/To discuss (explain here:)
3. What is program duration?
  a. Less than 6 months, STOP SCREENING
  b. 6 months
  c. 6–12 months
  d. 12 months
  e. Not reported/unclear
  f. Other (please type:)
4. Excerpted relevant findings
5. Sample size (n=?) – include units
6. What is the setting?
  a. General/MedSurg
  b. Specific clinical area, eg, ICU/NICU/PICU/OR, etc. (specify:)
  c. Unclear/not reported (explain here:)
7. Is program accredited?
  a. Yes
  b. No
  c. Not reported
8. What are the quantitative outcomes of the program? (Select all)
  a. Retention/attrition
  b. Satisfaction
  c. Competency
  d. Cost
  e. Confidence/“Readiness for Practice”
  f. Patient level outcomes
  g. Turnover
  h. Other
9. What are the components and implementation characteristics?
  a. Lectures
  b. Mentor
  c. Preceptor
  d. A project
  e. Other, specify here