# APPENDIX B SEARCH STRATEGIES

Search Date: 2015 – 2022 | | Search Statement | Results
PubMed/MEDLINE; [2015 – 2022] | 1 | “new graduate nurs*”[tiab] OR “newly graduated nurs*”[tiab] OR “nurse graduate*”[tiab] OR “post graduate nurs*”[tiab] OR “newly qualified nurs*”[tiab] OR “newly licensed nurs*”[tiab] OR “new nurs*”[tiab] OR “novice nurs*”[tiab] OR “neophyte nurs*”[tiab] OR “early career nurs*”[tiab] OR “post-registration nurs*”[tiab] OR “newly registered nurs*”[tiab] OR “graduate nurse transition*”[tiab] | 4,349
PubMed/MEDLINE; [2015 – 2022] | 2 | transition*[tiab] OR internship*[tiab] OR extern*[tiab] OR mentorship*[tiab] OR preceptor*[tiab] OR “nurse residenc*”[tiab] OR NRP[tiab] OR train*[tiab] OR simulation[tiab] OR “simulator*”[tiab] OR orientation*[tiab] OR “inservice train*”[tiab] OR onboard*[tiab] OR “on-board*”[tiab] OR “clinical competenc*”[tiab] OR “professional competenc*”[tiab] OR “peer support*”[tiab] OR “support group*”[tiab] OR “transitional support”[tiab] OR “rotational train*”[tiab] OR transition-to-practice[tiab] OR “transition to practice”[tiab] OR “clinical supervis*”[tiab] OR “clinical mentor*”[tiab] OR “clinical practicum”[tiab] OR “academic-practice partnership*”[tiab] OR socialization[tiab] OR “Education, Nursing, Continuing”[Mesh] OR “Education, Nursing, Graduate”[Mesh] OR “Inservice Training”[Mesh] OR “Competency-Based Education”[Mesh] | 2,023,346
PubMed/MEDLINE; [2015 – 2022] | 3 | #1 AND #2 | 2,276
PubMed/MEDLINE; [2015 – 2022] | 4 | (systematic*[ti] AND review[ti]) OR “systematic overview*”[ti] OR “Cochrane review*”[ti] OR “systemic review*”[ti] OR “scoping review”[ti] OR “scoping literature review”[ti] OR “mapping review”[ti] OR “umbrella review*”[ti] OR “review of reviews”[ti] OR “overview of reviews”[ti] OR meta-review[ti] OR “integrative review”[ti] OR “integrated review”[ti] OR “integrative overview”[ti] OR meta-synthesis[ti] OR “meta synthesis”[ti] OR metasynthesis[ti] OR “quantitative review”[ti] OR “quantitative synthesis”[ti] OR “research synthesis”[ti] OR meta-ethnography[ti] OR “systematic literature search*”[ti] OR “systematic literature research”[ti] OR meta-analy*[ti] OR (meta-analytic*[ti] AND review[ti]) OR meta-analysis[pt] OR systematic[sb] | 381,667
PubMed/MEDLINE; [2015 – 2022] | 5 | ((search*[tiab] OR MEDLINE[tiab] OR PubMed[tiab] OR Embase[tiab] OR Cochrane[tiab] OR CINAHL[tiab] OR “Joanna Briggs”[tiab] OR “JBI”[tiab] OR Scopus[tiab] OR “Web of Science”[tiab] OR “sources of information”[tiab] OR “data sources”[tiab] OR “following databases”[tiab] OR “bibliographic database*”[tiab] OR hand-search*[tiab] OR “relevant journals”[tiab] OR manual search*[tiab]) AND (“study selection”[tiab] OR “selection criteria”[tiab] OR “eligibility criteria”[tiab] OR “inclusion criteria”[tiab] OR “exclusion criteria”[tiab])) OR “systematic review”[pt] | 259,682
PubMed/MEDLINE; [2015 – 2022] | 6 | (letter[pt] OR editorial[pt] OR comment[pt] OR “case reports”[pt] OR “historical article”[pt] OR report[ti] OR protocol[ti] OR protocols[ti] OR withdrawn[ti] OR “retraction of publication”[pt] OR “retraction of publication as topic”[Mesh] OR “retracted publication”[pt] OR reply[ti] OR “published erratum”[pt]) | 5,041,240
PubMed/MEDLINE; [2015 – 2022] | 7 | (#4 OR #5) NOT #6 | 371,864
PubMed/MEDLINE; [2015 – 2022] | 8 | #3 AND #7 | 108
PubMed/MEDLINE; [2015 – 2022] | 9 | #8 AND ((2015/1/1:2022/12/31[pdat]) AND (english[Filter])) | 89
PubMed/MEDLINE; [2015 – 2022] | 10 | #9 AND (30965203 33751999 30204714); Sentinel articles: 30965203, 33751999, 30204714 | 2
CINAHL Plus; [2015 – 2022] | 1 | TI(“new graduate nurs*” OR “newly graduated nurs*” OR “nurse graduate*” OR “post graduate nurs*” OR “newly qualified nurs*” OR “newly licensed nurs*” OR “new nurs*” OR “novice nurs*” OR “neophyte nurs*” OR “early career nurs*” OR “post-registration nurs*” OR “newly registered nurs*”) OR AB(“new graduate nurs*” OR “newly graduated nurs*” OR “nurse graduate*” OR “post graduate nurs*” OR “newly qualified nurs*” OR “newly licensed nurs*” OR “new nurs*” OR “novice nurs*” OR “neophyte nurs*” OR “early career nurs*” OR “post-registration nurs*” OR “newly registered nurs*”) OR MM(“New Graduate Nurses” OR “Novice Nurses”) | 9,876
CINAHL Plus; [2015 – 2022] | 2 | TI(transition* OR internship* OR extern* OR mentorship* OR preceptor* OR “nurse residenc*” OR NRP OR train* OR simulation OR “simulator*” OR orientation* OR “inservice train*” OR onboard* OR “on-board*” OR “clinical competenc*” OR “professional competenc*” OR “peer support*” OR “support group*” OR “transitional support” OR “rotational train*” OR transition-to-practice OR “transition to practice” OR “clinical supervis*” OR “clinical mentor*” OR “clinical practicum” OR “academic-practice partnership*” OR socialization) OR AB(transition* OR internship* OR extern* OR mentorship* OR preceptor* OR “nurse residenc*” OR NRP OR train* OR simulation OR “simulator*” OR orientation* OR “inservice train*” OR onboard* OR “on-board*” OR “clinical competenc*” OR “professional competenc*” OR “peer support*” OR “support group*” OR “transitional support” OR “rotational train*” OR transition-to-practice OR “transition to practice” OR “clinical supervis*” OR “clinical mentor*” OR “clinical practicum” OR “academic-practice partnership*” OR socialization) OR MM(“Transitional Programs” OR “Entry Into Practice”) | 550,643
CINAHL Plus; [2015 – 2022] | 3 | S1 AND S2 | 3,745
CINAHL Plus; [2015 – 2022] | 4 | TI((systematic* AND review) OR “systematic overview*” OR “Cochrane review*” OR “systemic review*” OR “scoping review” OR “scoping literature review” OR “mapping review” OR “umbrella review*” OR “review of reviews” OR “overview of reviews” OR meta-review OR “integrative review” OR “integrated review” OR “integrative overview” OR meta-synthesis OR “meta synthesis” OR metasynthesis OR “quantitative review” OR “quantitative synthesis” OR “research synthesis” OR meta-ethnography OR “systematic literature search*” OR “systematic literature research” OR meta-analy* OR (meta-analytic* AND review)) OR PT(meta-analysis) | 152,385
CINAHL Plus; [2015 – 2022] | 5 | TI((search* OR MEDLINE OR PubMed OR Embase OR Cochrane OR CINAHL OR “Joanna Briggs” OR “JBI” OR Scopus OR “Web of Science” OR “sources of information” OR “data sources” OR “following databases” OR “bibliographic database*” OR hand-search* OR “relevant journals” OR manual search*) AND (“study selection” OR “selection criteria” OR “eligibility criteria” OR “inclusion criteria” OR “exclusion criteria”)) OR AB((search* OR MEDLINE OR PubMed OR Embase OR Cochrane OR CINAHL OR “Joanna Briggs” OR “JBI” OR Scopus OR “Web of Science” OR “sources of information” OR “data sources” OR “following databases” OR “bibliographic database*” OR hand-search* OR “relevant journals” OR manual search*) AND (“study selection” OR “selection criteria” OR “eligibility criteria” OR “inclusion criteria” OR “exclusion criteria”)) OR PT(“systematic review”) | 150,857
CINAHL Plus; [2015 – 2022] | 6 | PT(letter OR editorial OR comment OR “case report*” OR “historical article”) OR TI(report OR protocol* OR withdrawn OR “retraction of publication” OR “retracted publication” OR reply OR “published erratum”) | 916,682
CINAHL Plus; [2015 – 2022] | 7 | (S4 OR S5) NOT S6 | 201,531
CINAHL Plus; [2015 – 2022] | 8 | S3 AND S7 | 174
CINAHL Plus; [2015 – 2022] | 9 | S8; Limits: Published Date: 20150101-20231231; Language: English; Source Type: Academic Journals; Geographic: USA | 128
| | Total | 140
| | Total after deduplication | 116
Search Date: 2010 – 2022 | | Search Statement | Results
PubMed; [2010 – 2022] | 1 | “new graduate nurs*”[tiab] OR “newly graduated nurs*”[tiab] OR “nurse graduate*”[tiab] OR “post graduate nurs*”[tiab] OR “newly qualified nurs*”[tiab] OR “newly licensed nurs*”[tiab] OR “new nurs*”[tiab] OR “novice nurs*”[tiab] OR “neophyte nurs*”[tiab] OR “early career nurs*”[tiab] OR “post-registration nurs*”[tiab] OR “newly registered nurs*”[tiab] OR “graduate nurse transition*”[tiab] | 4,354
PubMed; [2010 – 2022] | 2 | transition*[tiab] OR internship*[tiab] OR extern*[tiab] OR mentorship*[tiab] OR preceptor*[tiab] OR “nurse residenc*”[tiab] OR NRP[tiab] OR train*[tiab] OR simulation[tiab] OR “simulator*”[tiab] OR orientation*[tiab] OR “inservice train*”[tiab] OR onboard*[tiab] OR “on-board*”[tiab] OR “clinical competenc*”[tiab] OR “professional competenc*”[tiab] OR “peer support*”[tiab] OR “support group*”[tiab] OR “transitional support”[tiab] OR “rotational train*”[tiab] OR transition-to-practice[tiab] OR “transition to practice”[tiab] OR “clinical supervis*”[tiab] OR “clinical mentor*”[tiab] OR “clinical practicum”[tiab] OR “academic-practice partnership*”[tiab] OR socialization[tiab] OR “Education, Nursing, Continuing”[Mesh] OR “Education, Nursing, Graduate”[Mesh] OR “Inservice Training”[Mesh] OR “Competency-Based Education”[Mesh] | 2,026,492
PubMed; [2010 – 2022] | 3 | #1 AND #2 | 2,281
PubMed; [2010 – 2022] | 4 | #3 AND ((2010/1/1:2022/12/31[pdat]) AND (english[Filter])) | 1,501
PubMed; [2010 – 2022] | 5 | #4 AND (30965203 33751999 30204714) | 3
CINAHL Plus; [2010 – 2022] | 1 | TI(“new graduate nurs*” OR “newly graduated nurs*” OR “nurse graduate*” OR “post graduate nurs*” OR “newly qualified nurs*” OR “newly licensed nurs*” OR “new nurs*” OR “novice nurs*” OR “neophyte nurs*” OR “early career nurs*” OR “post-registration nurs*” OR “newly registered nurs*”) OR AB(“new graduate nurs*” OR “newly graduated nurs*” OR “nurse graduate*” OR “post graduate nurs*” OR “newly qualified nurs*” OR “newly licensed nurs*” OR “new nurs*” OR “novice nurs*” OR “neophyte nurs*” OR “early career nurs*” OR “post-registration nurs*” OR “newly registered nurs*”) | 6,424
CINAHL Plus; [2010 – 2022] | 2 | TI(transition* OR internship* OR extern* OR mentorship* OR preceptor* OR “nurse residenc*” OR NRP OR train* OR simulation OR “simulator*” OR orientation* OR “inservice train*” OR onboard* OR “on-board*” OR “clinical competenc*” OR “professional competenc*” OR “peer support*” OR “support group*” OR “transitional support” OR “rotational train*” OR transition-to-practice OR “transition to practice” OR “clinical supervis*” OR “clinical mentor*” OR “clinical practicum” OR “academic-practice partnership*” OR socialization) OR AB(transition* OR internship* OR extern* OR mentorship* OR preceptor* OR “nurse residenc*” OR NRP OR train* OR simulation OR “simulator*” OR orientation* OR “inservice train*” OR onboard* OR “on-board*” OR “clinical competenc*” OR “professional competenc*” OR “peer support*” OR “support group*” OR “transitional support” OR “rotational train*” OR transition-to-practice OR “transition to practice” OR “clinical supervis*” OR “clinical mentor*” OR “clinical practicum” OR “academic-practice partnership*” OR socialization) | 550,178
CINAHL Plus; [2010 – 2022] | 3 | MM((“New Graduate Nurses” OR “Novice Nurses”) AND (“Transitional Programs” OR “Entry Into Practice”)) | 498
CINAHL Plus; [2010 – 2022] | 4 | (S1 AND S2) OR S3 | 2,946
CINAHL Plus; [2010 – 2022] | 5 | S4; Limits: Published Date: 20150101-20231231; Language: English; Source Type: Academic Journals | 1,659
| | Total | 3160
| | Total after deduplication | 2106