# APPENDIX A PEER REVIEW COMMENTS AND RESPONSES

Comment # | Reviewer # | Comment | Author Response
Are the objectives, scope, and methods for this review clearly described?
1 | 1 | Yes | None
2 | 2 | Yes | None
3 | 4 | Yes | None
4 | 5 | Yes | None
5 | 6 | Yes | None
6 | 7 | Yes | None
7 | 8 | Yes | None
8 | 9 | Yes | None
9 | 12 | Yes | None
10 | 14 | Yes | None
Is there any indication of bias in our synthesis of the evidence?
11 | 1 | No | None
12 | 2 | No | None
13 | 4 | No | None
14 | 5 | No | None
15 | 6 | No | None
16 | 7 | No | None
17 | 8 | No | None
18 | 9 | No | None
19 | 12 | No | None
20 | 14 | No | None
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
21 | 1 | No | None
22 | 2 | No | None
23 | 4 | No | None
24 | 5 | No | None
25 | 6 | No | None
26 | 7 | No | None
27 | 8 | No | None
28 | 9 | No | None
29 | 12 | No | None
30 | 14 | No | None
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
Key Findings
31 | 2 | Page V - Line 60 - Missing the word “of” between implementation and nurse | Language has been revised, aligned with comment 35 to read “implementing nursing residency programs.”
32 | 5 | P v, line 54: Consider using another word for “tenure.” “Tenure” is not usually associated with RN retention. Suggestion--First-year nurses have the highest turnover rate of all hospital-based RNs. The reference for this citation is only based on hospitals. In reference 1 see page 2, the first line under Methodology. | We have updated this language.
33 | 5 | P. v, line 56: Consider changing “brand-new environment” to new work environment. | We have updated this language.
34 | 5 | P. v, line 58: IOM report. Add the year, 2011. It will help clarify which of the two IOM reports on nursing are being cited. | We have added the year.
35 | 5 | P. v, line 60: for consistency change to “implementing” nurse residency programs | We have updated this language.
36 | 5 | P. vi, line 4: for consistency change to “improving patient outcomes” | We have updated this language.
37 | 5 | P. vi, line 9: delete “train” and consider to “assist with the transition of ...” | We have made this revision.
| | | We have updated this language.
Background
38 | 4 | Pg 4 - Line 34 to 35 - May want to consider adding a comma after “In general” | We have made this revision.
39 | 5 | P. 4, line 7: same comment as 1. (“Consider using another word for “tenure.” “Tenure” is not usually associated with RN retention. Suggestion--First-year nurses have the highest turnover rate of all hospital-based RNs. The reference for this citation is only based on hospitals. In reference 1 see page 2, the first line under Methodology.”) | We have updated this language.
40 | 5 | P. 4, line 14: Delete the sentence and add, New nurse graduates can benefit from comprehensive transition to practice programs that assist with the “...process of professional role socialization...” and help improve retention. Citation--Commission on Collegiate Nursing Education. (2021). Standards for accreditation if entry-to-practice nurse residency programs. Pg. 4. https://www.aacnnursing.org/Portals/42/CCNE/PDF/CCNE-Entry-to-Practice-Residency-Standards-2021.pdf | We have made this revision.
41 | 5 | P. 4, line 41: delete “to train new graduate nurses” and add, “for these types of programs.” | We have made this revision.
42 | 6 | page 4, line 15 - citation? Seems out of place in this paragraph, consider connecting it back to the previous sentences | We have revised this section and referenced accordingly; this citation is now with the appropriate text about transition shock.
43 | 6 | page 4, line 36 - first time using RNTTP, consider spelling out or referring to it as RNTTP when first mentioned in line 30 | We have made this revision.
44 | 6 | page 4, line 37 - “last longer” consider less causal language | We have made this revision.
45 | 6 | page 4, line 38 - while the background delineates RNTTP and residency programs, all future mentions in the paper only refer to RNTTP. Consider mentioning this moving forward to ensure the capture of both programs | We have further described our RNTTP focus and its relationship to residency programs.
46 | 6 | page 5, line 6 - use abbreviation TTP vs spelling out | We have harmonized our acronym use throughout.
Methods – Searching and Screening
47 | 6 | page 7 searching and screening - any exclusion criteria based on country that the study took place? | Yes, we did restrict our focus to programs implemented in OECD member countries to approximate US health care delivery context. This is described in the eligibility criteria table in the Key Questions and Eligibility Criteria section.
48 | 7 | The search terms used for screening the databases for literature did not include “nurse residency program” which the literature uses separately from “transition to practice”. There could be more reviews out there that were missed in this analysis | Our search terms did include a number of terms listed in Appendix A that were variations on the terms listed in the report narrative, and one of these was “nurse residenc*” as appearing in either title or abstract of the citation. We have revised the text to be more clear about the terms in the report narrative being examples from a broader set of terms.
49 | 14 | In Methods- Searching and Screening (page 7), the authors stated that the search for systematic reviews was from 1/1/15 to 12/15/22, and the search for original research studies was from 1/1/10-12/21/22. It makes sense to me that the search for original research papers went to earlier years because the review papers contained studies prior to the review time. However, I wonder why the end time was different between the 2 searches? Additionally, when was the systematic review for this report conducted? Given we are already in the second half of 2024 right now, is it possible to include more recent studies from 2023? | The search for primary literature was conducted later, or more recently, because it was part of our analysis of the reviews, which we had already searched for and were in the process of synthesizing. We do hope to update our searches for future products, but that is currently out of scope for this report.
Results – Overview of Included Reviews
50 | 14 | 1). In the first paragraph, the authors stated that 6 reviews were excluded at the full-text screening for ineligible study designs. Can the authors expand a little more on what “ineligible study design” means here? | We have revised this sentence to clarify with examples of ineligible publications, such as commentaries or editorials.
51 | 14 | 2). In the last paragraph on this page, the authors wrote that “Nine reviews were precluded from further discussion...”. I am confused where these 9 reviews come from. From the earlier paragraphs in this section, I learned that 19 systematic reviews were included out of 140 reviews and the flow chart (Figure 1) was very clear on the exclusion step by step. But I am having a hard time connecting these “nine reviews” mentioned here with the 140 reviews. | We have revised and now discuss these nine reviews in a separate section, called “Reviews not discussed in Key Questions,” to clarify that these are reviews that met inclusion criteria and were included in the gap analysis, but not specifically used as evidence for the two Key Questions.
52 | 14 | For Table 2, can the authors give some information on the difference between scoping reviews, integrative reviews, and systematic reviews? Maybe in the footnote of the Table? | Distinguishing between these methodologies is tough because of the variability with how different authors interpret and operationalize them, and because there are various perspectives on each.
Results – Overview of Included Original Research
53 | 2 | Thank you so much for your effort and expertise!; Suggestion: clarify Figure 4 on page 21. Only gray shaded shapes are described in the notes. Unsure what green and blue mean or if there are differences with the boxes, diamonds, and circles. | This figure was removed.
54 | 7 | Additionally, the review of primary studies did not include some of the largest longitudinal studies in the literature from the inception of nurse residency programs. Much of this research focused on the characteristics of effective programs including length, structure, etc. This could be because NRPs have only been growing in popularity since the IOM report so some of the seminal literature dates back further than the search included. | Reviewer did not respond to request for additional information that we sought to identify the literature they describe, including these largest longitudinal studies. We have also further reorganized our report to emphasize the role our primary studies searches played in our analyses, namely, to better understand our review of reviews coverage of the evidence base.
Results – Key Question 1
55 | 4 | Pg 23 - Line 8 - Reads “Case-Fink” and I believe it should be Casey-Fink | We have updated this language.
56 | 7 | Additionally, the key question 1 regarding the effectiveness of improving nurse outcomes is already well cited in the literature and not providing new information. A more effective question would be if the programs are impacting patient outcomes. | Our Key Questions are developed in collaboration with our operational partners, and are meant to reflect their needs. While we all agree that patient outcomes would be of interest, there were no published reports that our review identified that covered patient outcomes, and so we were unable to include them further.
57 | 14 | Page 22, “Key question #1: ARE TRANSITION TO PRACTICE...”. I understand the authors were trying to first focus on the 2 reviews with relatively good quality and then talk about the 6 reviews with lower quality. However, the information was somewhat disconnected and it’s hard for me to reconcile the information contained in different reviews. The section may benefit from adding a summary paragraph and explicitly summarize the findings from different reviews. | We have substantially revised the Key Question 1 and other results section of the report to be more cogent, and to highlight our key findings.
Results – Key Question 2
58 | 7 | Key question 2 which included a review of primary research missed some research on this topic published in 2022 and some very seminal work out there on NRPs | We did not include primary research in this systematic review of reviews as evidence towards either Key Question. We have substantially revised the results section to increase clarity.
General Report Comments
59 | 5 | Please re-consider the use of the terms, training, brand new environment, and tenure. Registered nurses have to complete a rigorous educational program along with clinical experiences. While they need help with the transition to professional practice, they are highly trained health professionals. These terms imply otherwise and do not accurately reflect the experience. | We have revised language throughout to improve this framing.
60 | 7 | Recommend expanding this search of primary research to help answer the questions to include seminal work and focusing more on nurse residency programs. Also recommend including a SME on this review to support the rigor of this analysis. | While we would love to continue this work and conduct a more rigorous (and up-to-date) analysis of the primary research, this was out of scope for the current systematic review of reviews.; We originally identified a team of reviewers with appropriate expertise, however all reviewer participation is voluntary, and our SME focus was appropriately directed towards other professional priorities during the course of our project. We were unable to identify another team member with appropriate expertise and bandwidth for participation.
61 | 12 | Thank you for the opportunity to review this timely and important work. I did a quick pubmed search with the listed search terms for 2022–2024 and pulled 81 pubs. Obviously not all would be included, but, that is many pubs on a niche topic.; Your work once published will serve as a call to action for improved eval methods and program description in pubs. | As noted in response to comment 60, we would very much hope that future work would be able to do a rigorous analysis of the original research studies in this area.