# ABBREVIATIONS TABLE

Abbreviation: Definition
FT: Full text
IOM: Institute of Medicine
IR: Integrative review
NGN: New graduate nurses
NQN: Newly qualified nurses
NRP: Nurse residency programs
ONS: VA Office of Nursing Services
PICO: Population, intervention, comparator, outcome
REA: Rapid evidence assessment
RN: Registered Nurse
RNTTP: RN transition-to-practice residency/fellowship program
ScR: Scoping review
SysR: Systematic review
VHA: Veterans Health Administration