# REFERENCES

1 Vickers A, Zollman C. Massage therapies. BMJ. 1999;319(7219):1254–7.10550095
2 Veterans Health Administration. VHA Directive 1137. 2017.
3 The GRADE Working Group. Grading of recommendations assessment, development and evaluation (GRADE).
4 Agency for Healthcare Research and Quality. Evidence-based Practice Center. https://www.ahrq.gov/research/findings/evidence-based-reports/index.html
5 Nikolakopoulou A, Higgins JPT, Papakonstantinou T, CINeMA: An approach for assessing confidence in the results of a network meta-analysis. PLoS Med. Apr 2020;17(4):e1003082. doi:10.1371/journal.pmed.1003082 32243458
6 Gu X, Zhang L, Yuan H, Zhang M. Analysis of the efficacy of abdominal massage on functional constipation: A meta-analysis. Heliyon. Jul 2023;9(7):e18098. doi:10.1016/j.heliyon.2023.e18098 37496907
7 Jiang ZF, Liu G, Sun XX, Auricular acupressure for constipation in adults: a systematic review and meta-analysis. Front Physiol. 2023;14:1257660. doi:10.3389/fphys.2023.1257660 37908337
8 Lin WF, Zhong MF, Zhou QH, Efficacy of complementary and integrative medicine on health-related quality of life in cancer patients: a systematic review and meta-analysis. Cancer Manag Res. 2019;11:6663–6680. doi:10.2147/cmar.S195935 31413628
9 Tan MY, Shu SH, Liu RL, Zhao Q. The efficacy and safety of complementary and alternative medicine in the treatment of nausea and vomiting during pregnancy: A systematic review and meta-analysis. Review. Front Public Health. Mar 2023;11:17. 1108756. doi:10.3389/fpubh.2023.1108756 36969661
10 Bi L, Gao W, Zhang X, Li N, Han J, Shi M. Efficacy of traditional Chinese medicine external therapy on sleep quality in patients with cancer: A systematic review and network meta-analysis. Asia Pac J Oncol Nurs. Nov 2023;10(11):100308. doi:10.1016/j.apjon.2023.100308 37928412
11 Natale P, Ruospo M, Saglimbene VM, Palmer SC, Strippoli GF. Interventions for improving sleep quality in people with chronic kidney disease. Cochrane Database Syst Rev. May 26 2019;5(5):Cd012625. doi:10.1002/14651858.CD012625.pub2 31129916
12 Yin Z, Li Y, Bao Q, Comparative efficacy of multiple non-pharmacological interventions for behavioural and psychological symptoms of dementia: A network meta-analysis of randomised controlled trials. Int J Ment Health Nurs. Jun 2024;33(3):487–504. doi:10.1111/inm.13254 38012101
13 Huang Q, Zhan MQ, Hu Z. Auricular Acupressure for Dry Eye Disease: A Systematic Review and Meta-Analysis of Randomized Controlled Trials. Review. Med Lith. Jan 2023;59(1):18. 177. doi:10.3390/medicina59010177
14 Chopra P, Ayers CK, Antick JR, Kansagara D, Kondo K. The Effectiveness of Depression Treatment for Adults with ESKD: A Systematic Review. Kidney360. Mar 25 2021;2(3):558–585. doi:10.34067/kid.0003142020 35369008
15 Natale P, Ju A, Strippoli GF, Interventions for fatigue in people with kidney failure requiring dialysis. Cochrane Database Syst Rev. Aug 31 2023;8(8):Cd013074. doi:10.1002/14651858.CD013074.pub2 37651553
16 Vijayakumar V, Boopalan D, Ravi P, Effect of massage on blood pressure in patients with hypertension: A meta-analysis. J Bodyw Mov Ther. Jan 2024;37:109–114. doi:10.1016/j.jbmt.2023.11.028 38432790
17 Sinha S, Gabriel VA, Arora RK, Interventions for postburn pruritus. Cochrane Database Syst Rev. Jun 5 2024;6(6):Cd013468. doi:10.1002/14651858.CD013468.pub2 38837237
18 Yang JM, Li ZQ, Ye H, Effects of foot reflexology massage on pregnant women: a systematic review and meta-analysis of randomized controlled studies. Sci Rep. Jan 10 2024;14(1):1012. doi:10.1038/s41598-023-51107-y 38200035
19 Xie W, Ye F, Yan X, Acupressure can reduce preoperative anxiety in adults with elective surgery: A systematic review and meta-analysis of randomised controlled trials. Int J Nurs Stud. Sep 2023;145:104531. doi:10.1016/j.ijnurstu.2023.104531 37321140
20 Mak S, Allen J, Begashaw M, Use of Massage Therapy for Pain, 2018–2023: A Systematic Review. JAMA Netw Open. Jul 1 2024;7(7):e2422259. doi:10.1001/jamanetworkopen.2024.22259 39008297