# ACKNOWLEDGMENTS

The authors are grateful to Emily Lawson, MSLIS, AHIP for literature searching, external peer reviewers, and the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who help ensure relevance of the review topic to the VA, contribute to the development of and approve final project scope and timeframe for completion, provide feedback on the draft report, and provide consultation on strategies for dissemination of the report to the field and relevant groups.

- Juli Olson, DC, DACM
  National Lead Clinical Champion
  Integrative Health Coordinating Center
  VHA Office of Patient Centered Care & Cultural Transformation
- Sharon M. Weinstein, MD, MT, FAAHPM
  VA National Lead, Massage Therapy
  Integrative Health Coordinating Center
  VHA Office of Patient Centered Care & Cultural Transformation
- Alison Whitehead, MPH, C-IAYT, E-RYT200
  National Program Lead
  Integrative Health Coordinating Center
  VHA Office of Patient Centered Care & Cultural Transformation