# Executive Summary

## KEY FINDINGS

► We identified 14 reviews of massage therapy published since 2018 that assessed the certainty of evidence for their conclusions and thus were included in the evidence map. These reviews covered 9 health conditions, including sleep and mental health conditions in persons with cancer, dry eye disease, dementia, functional constipation, hypertension, kidney disease, post-burn pruritus, pregnancy, and pre-operative anxiety.
► One review concluded with high certainty of evidence that massage therapy has a potential beneficial effect on functional constipation. Three reviews concluded with moderate certainty of evidence that massage therapy has a potential beneficial effect on sleep quality in cancer patients, sleep quality in people with chronic kidney disease, and depression in individuals living with dementia.
► Evidence about adverse events was collected by 7 of 14 (50%) reviews, with most reviews reporting no serious adverse events. One review about the beneficial effect of auricular acupressure as treatment for functional constipation included a low certainty of evidence rating for adverse events.

## INTRODUCTION

Massage therapy is a popular and widely accepted complementary and integrative health (CIH) modality for treatment of certain adult health conditions. With its popularity and long history in practice, the rigorous evidence of beneficial effect of massage therapy is growing.

## METHODS

### Data Sources and Searches

Search strategies were developed in consultation with a medical librarian who is expert in literature reviews. We used terms such as massage, myofascial, acupressure, and systematic review and conducted searches from July 2018 to July 2024 in bibliographic databases: PubMed, Allied and Complementary Medicine Database (AMED), Cumulated Index to Nursing and Allied Health Literature (CINAHL), Cochrane Database of Systematic Reviews (CDSR), and Web of Science. (see Appendix for complete search strategies).

### Study Selection

Eligible publications were systematic reviews of studies that examined the efficacy or effectiveness of massage therapy delivered by a health professional in non-painful adult health conditions. In general, any soft-tissue manipulation technique described as “massage therapy” was considered eligible; these included Tuina, Swedish massage, myofascial release, acupressure, etc. Studies were required to compare massage therapy to a sham/placebo, usual care, or other active therapies (exercise, health education, etc). An active therapy is defined as a therapy intended to have an intervention-specific effect that is not sham or placebo. Further details about the study selection process are described in the main report.

### Data Abstraction and Presentation

Each included systematic review had data abstracted by 1 reviewer and verified by a second reviewer. Abstracted data included number of studies included in the review that had massage therapy as the intervention, treated condition, type of massage therapy, comparators, certainty of evidence rating, and certainty of evidence conclusion(s) relevant to the effect of massage therapy on a non-painful adult health condition.

## RESULTS

We identified 3,104 potentially relevant citations. A total of 190 publications were retained for further review and potential inclusion on the map. We included 14 publications (ES Figure). In this map, bubble color denotes intervention type, shape denotes type of comparator, and size of shape indicates the number of primary studies included in the review.

ES Figure Evidence Map

Evidence map of conclusions from systematic reviews on massage therapy for non-painful adult health conditions. Reviews found either a potential benefit or no benefit compared to various comparison treatments, with varying levels of certainty in the evidence. Conclusions are categorized by certainty (high, moderate, low/very low) and visually coded by intervention type, comparator, and number of included studies.

Three high-level observations can be made from the evidence mapping process:

1) We identified 1 review with high certainty of evidence and 3 reviews with moderate certainty of evidence of potential benefit of massage therapy. The high certainty of evidence conclusion was about functional constipation. The moderate certainty of evidence conclusions were about sleep quality in cancer patients, sleep quality in people with chronic kidney disease, and depression in individuals living with dementia.
2) The majority of primary studies in included reviews compared massage therapy to routine or usual care. A handful of comparators were alternate interventions such as artificial tears in a review about dry eye disease and nutritional supplements in a review about nausea and vomiting during pregnancy.
3) Half of the included reviews were focused on symptom improvements in specific conditions; the rest of the reviews focused on outcomes in specific populations. Two reviews focused on sleep quality, with 1 review about patients with cancer and the other review about chronic kidney disease. Two reviews described treatments for depression, with 1 review about individuals living with dementia and the second review about patients with end-stage renal disease. The other reviews were about peri-operative anxiety, fatigue in dialysis patients, and health-related quality of life in cancer patients.

Evidence about adverse events was collected by 50% of the included reviews and no serious adverse events were reported. While 7 of 14 reviews mentioned adverse events, only 1 review included a certainty of evidence conclusion for adverse events.

## DISCUSSION

### Key Findings

Our evidence map includes 14 systematic reviews published since July 2018, and from these, 1 review reported high certainty of evidence and 3 reviews reported moderate certainty of evidence for beneficial effect of massage therapy for non-painful adult health conditions.

### Future Research

For conditions of priority to the VA that currently do not have at least moderate-certainty evidence supporting use of massage therapy, new studies that address limitations of existing research are needed. More research on long-term effects, as well as the effect of frequency or duration of treatment, will also increase the evidence base for massage therapy. While no serious adverse events have been reported by reviews that had included data about adverse events, more comprehensive reporting of adverse events in primary studies is needed to inform statements about safety of massage therapy for non-painful health conditions.

### Conclusions

This evidence map about massage therapy included 14 reviews published since 2018 and showed that the certainty of evidence for massage therapy’s benefit on non-painful adult health conditions has been estimated for 9 health conditions or symptoms. More high-quality randomized controlled trials are needed to provide a stronger evidence base to assess the effect of massage therapy on a wider range of adult health conditions.