# DISCUSSION

We identified 14 reviews of massage therapy published since 2018 that assessed the certainty of evidence for their conclusions and thus were included in the evidence map. These reviews covered 9 health conditions, including sleep and mental health conditions in persons with cancer, dry eye disease, dementia, functional constipation, hypertension, kidney disease, post-burn pruritus, pregnancy, and pre-operative anxiety. From these, 1 review on functional constipation reported high certainty of evidence, and 3 reviews on sleep quality in individuals with chronic kidney disease, depression in individuals living with dementia, and sleep quality in cancer patients reported moderate certainty of evidence for beneficial effect of massage therapy.

A strength of this evidence map is that only reviews where certainty was formally assessed are included. This means a review is only eligible for this map if authors of systematic reviews had formally assessed the certainty (or strength) of their conclusions about massage therapy. Far too often do readers find systematic reviews conclude with words to the effect of: “Massage therapy may be an effective therapy for a specific condition, but more research is needed.” It is therefore difficult to ascertain how much certainty is contained in the word “may.”

## LIMITATIONS

A limitation common to all systematic reviews is that we may not have identified all the potentially eligible evidence. If a systematic review was published in a journal not indexed in any of the 5 databases we searched, and we did not identify it as part of our search of references of included publications, then we would have missed it. Nevertheless, our search strategy did identify more than 190 publications about massage therapy for non-painful adult health conditions published since 2018, so we did not suffer from a lack of potential reviews to evaluate.

The second limitation, common to evidence maps, is that we did not independently reevaluate the primary studies included in eligible systematic reviews; in other words, we took the conclusions of the authors of included systematic reviews “at face value.” Particular to this application of the mapping process, for the health conditions that had more than 1 eligible review (eg, functional constipation, fatigue in dialysis patients, nausea and vomiting during pregnancy), we only mapped the review we deemed most informative. This necessarily requires judgment, and others could disagree with that judgment. We included the citation for the review(s) excluded from the map for this “overlap” reason in the Supplementary Materials and interested readers can review it for additional information. As in all evidence-based products, and particularly in one such as this covering a large and complex evidence base, it is possible that there are errors of data extraction and compilation. We used dual review to minimize the chance of such errors, but if we are notified of errors, we will correct them.

Lastly, massage therapy is a broad term that is inclusive of many styles and techniques. We applied exclusion criteria determined a priori to help identify publications for inclusion in the evidence map. Despite that, there was still a lack of clarity in determining “what is massage therapy.” For instance, acupressure is sometimes termed acupuncture and other times considered massage therapy in literature, depending on author definition. We came across acupressure studies within reviews of acupuncture in the current search. In this case, we only reviewed publications that were explicitly labeled acupressure and acupuncture, and only included publications that had separately reported outcomes about acupressure only. This highlights a fundamental issue with examining the evidence base of massage therapy when there is ambiguity in defining what is considered massage therapy.

Another issue related to defining massage therapy is the tradeoff between “lumping” and “splitting.” Lumping involves a broader and more inclusive definition of massage therapy, and accounts for when authors of systematic reviews do not specify type of massage therapy or had reported outcomes for the effect of various types of massage therapy on a health condition together. Splitting refers to a narrower classification of massage therapy by type, such that reflexology is considered separate from myofascial release, which is considered separate from acupressure. Taking cues from literature where many authors have adopted the lumping approach to include different modalities of massage therapy in a systematic review, we also applied a broader definition of massage therapy as inclusion criteria for this review. The downside to this approach is that reviews which compared 2 massage therapy modalities (eg, massage therapy vs reflexology) were deemed ineligible for further review in the current map because the comparator needed to be an intervention other than massage therapy. In our current review, we encountered 2 such instances.

## FUTURE RESEARCH

For conditions of priority to the VA that currently do not have at least moderate-certainty evidence supporting use of massage therapy, new studies that address limitations of existing research are needed. More research on long-term effects, as well as the effect of frequency or duration of treatment, will also increase the evidence base for massage therapy. While no serious adverse events have been reported by reviews that had included data about adverse events, more comprehensive reporting of adverse events in primary studies is needed to inform statements about safety of massage therapy for non-painful health conditions. It is strongly recommended that future massage therapy research protocols include detailed descriptions of the techniques being utilized and the condition(s) being treated.

In our previous work “Evidence Map of Massage Therapy: Update from 2018–2023,” we had discussed the limitations of using sham treatment as a comparison group for massage therapy in primary studies.^20^ Sham refers to applying an intervention that is intended to mimic or simulate a real intervention but does not have the active therapeutic component. The goal is to make the sham sufficiently convincing that subjects cannot distinguish whether they are receiving the active or the sham treatment. Consensus has been there is no good sham to manual therapies. Exploring the component of various therapies that is attributable to the “therapeutic presence” (ie, part of medical massage therapy’s effect that is due to the experience of being touched by another human being) has yet to be studied.

## CONCLUSIONS

This evidence map about massage therapy included 14 reviews published since 2018 and showed that the certainty of evidence for massage therapy’s benefit on non-painful adult health conditions has been estimated for 9 health conditions or symptoms. More high-quality randomized controlled trials are needed to provide a stronger evidence base to assess the effect of massage therapy on a wider range of adult health conditions.