# RESULTS

## LITERATURE FLOW DIAGRAM

The literature flow diagram summarizes the results of the study selection process. A full list of excluded studies is provided in Supplementary Materials.

Literature flow diagram summarizing results of study selection process.

## OVERVIEW OF INCLUDED STUDIES

We identified 3,104 potentially relevant citations from database searches. After deduplicating these titles, we had a total of 1,563 titles for initial screening (see Literature Flow Diagram). We applied the inclusion and exclusion criteria to these titles and abstracts and excluded 1,373 publications. We reviewed 190 publications at full-text stage. A total of 176 publications were excluded at this stage for the following reasons: did not formally assess the certainty or strength or quality of the evidence (N = 143), not selected for map in favor of better review (N = 7), only 1 primary study about intervention of interest (N = 7), not a comparison of interest (N = 6), not about massage therapy (N = 4), incorrect use of GRADE (N = 3), outcomes not reported separately (N = 3), duplicate (N = 1), not a health condition (N = 1), and unable to locate full text (N = 1). See Supplementary Materials for a full list of excluded reviews. We included 14 publications in this map. See Table 1 for more details about the included reviews.

Table 1 Characteristics of Included Studies

Author, Year; Country | Condition (Outcome) | Intervention; Comparator; # of Included Studies | Certainty of Evidence Rating | Certainty of Evidence Conclusion
Lin, 2019^8^; China | Cancer; (Health-related quality of life) | Massage therapy; Active therapy/usual care; 2 | Low/Very low | Massage therapy “may improve the [health-related quality of life] of cancer patients.”
Bi, 2023^10^; China | Cancer; (Sleep quality) | Acupressure; Sham and active therapy/usual care; 8 | Low to moderate | Compared to usual care, sham, and active therapy, acupressure “demonstrated significant effects in improving sleep quality” in patients with cancer.
Bi, 2023^10^; China | Cancer; (Sleep quality) | Auricular Acupressure; Sham and active therapy/usual care; 8 | Low to moderate | Compared to usual care, sham, and active therapy, auricular acupressure “demonstrated significant effects in improving sleep quality” in patients with cancer.
Natale, 2019^11^; Sweden, Australia, Italy, New Zealand | Chronic kidney disease; (Sleep latency/fatigue) | Acupressure; Active therapy/usual care; 6 | Moderate | Compared with no acupressure, “acupressure probably slightly improved sleep latency [and] decreased fatigue” in people with chronic kidney disease.”
Natale, 2019^11^; Sweden, Australia, Italy, New Zealand | Chronic kidney disease; (Sleep quality/depression) | Acupressure; Active therapy/usual care; 6 | Low/Very low | Compared with no acupressure, “acupressure had uncertain effects on sleep quality [and] depression” in people with chronic kidney disease.”
Gu, 2023^6^; China | Functional constipation | Massage therapy; Sham and active therapy/usual care; 13 | High | Compared to active therapy, usual care, and no treatment, abdominal massage therapy “[improved] constipation severity scores” and can “positively affect the quality of life of patients with constipation.”
Jiang, 2023^7^; China | Functional constipation | Auricular acupressure; Sham and active therapy/usual care; 12 | Low/Very low | Compared to sham, conventional treatment, and usual care, auricular acupressure may be “effective treatment for constipation in adults to improving symptoms of constipation and increasing the frequency of spontaneous bowel movement.”
Yin, 2024^12^; China | Dementia (Depression) | Massage therapy; Active therapy/usual care; 2 | Moderate | Massage therapy plus [treatment as usual was] significantly more efficient than [treatment as usual] in reducing [Cornell Scale for Depression in Dementia](CSDD).”
Huang, 2023^13^; China | Dry eye disease | Auricular Acupressure; Sham and active therapy/usual care; 7 | Low/Very low | Compared to sham and active therapy, “auricular acupressure, as a sole intervention or in combination with artificial tears, may have a beneficial effect on dry eye disease.”
Chopra, 2021^14^; USA | End stage renal disease; (Depression severity) | Acupressure; Sham and active therapy/usual care; 2 | Low/Very low | “Acupressure is more effective than both usual care and sham acupressure for reducing depression severity in participants with end stage kidney disease. There is insufficient evidence to form conclusions about the comparison of acupressure to transcutaneous electrical acupoint stimulation (TEAS) for the reduction of depressive-symptom severity, fatigue, or sleep-quality improvement.”
Natale, 2023^15^; Italy, Australia, USA | Fatigue in dialysis patients | Massage Therapy; Active therapy/usual care; 7 | Low/Very low | “Compared to no intervention, massage may improve fatigue (7 studies) and increase energy (2 studies) in hemodialysis.”
Natale, 2023^15^; Italy, Australia, USA | Fatigue in dialysis patients | Acupressure; Sham and active therapy/usual care; 6 | Low/Very low | “Compared to placebo, [active therapy, and no treatment], acupressure may reduce fatigue (6 studies) in hemodialysis.”
Vijayakumar, 2024^16^; India | Hypertension | Massage Therapy; Active therapy/usual care; 6 | Low/Very low | “There is minimal reduction of [systolic blood pressure] and [diastolic blood pressure] after massage therapy intervention” compared to routine care.
Tan, 2023^9^; China | Nausea and vomiting during pregnancy | Acupressure; Sham and active therapy/usual care; 11 | Low/Very low | “Acupressure was superior to conventional medicine at the reduction of antiemetic drugs, and at the effective rate. Acupressure had the same effect as placebo at the effective rate” for treatment of nausea and vomiting during pregnancy.”
Sinha, 2025^17^; Canada, USA, India | Post-burn pruritus | Massage Therapy; Active therapy/usual care; 2 | Low/Very low | “Massage therapy may reduce mean itch intensity measured using an itching scale when compared to standard care.”
Yang, 2024^18^; China | Pregnancy (anxiety) | Massage Therapy; Active therapy/usual care; 6 | Low/Very low | Compared to active therapy/usual care, “foot reflexology massage reduced anxiety” in pregnant women.
Xie, 2023^19^; China | Pre-operative anxiety | Acupressure; Sham and active therapy/usual care; 24 | Low/Very low | Compared to sham and active therapy/usual care, “acupressure appears efficacious as a therapy for improving preoperative anxiety and physiological parameters amongst adults with elective surgery.”

### Characteristics of Included Reviews

The number of primary studies about massage therapy in the included reviews ranged from 2 studies to 24 studies. Four reviews included 2 to 5 studies,^8,12,14,17^ 6 reviews included 6 to 9 studies,^10,11,13,15,16,18^ and 4 reviews included more than 10 studies.^6,7,9,19^

The country of origin for reviews varied, with the largest number of reviews originating from China (N = 9),^6–10,12,13,18,19^ followed by the USA (N = 1)^14^ and India (N = 1).^16^ Three reviews were conducted by authors from multiple countries: Sweden, Australia, Italy, and New Zealand^11^; Canada, USA, and India^17^; and Italy, Australia, and USA.^15^

Of the 14 included reviews, 6 reviews were focused on massage therapy,^6,8,,12,16–18^ 4 reviews about acupressure,^9,11,14,19^ and 2 reviews about auricular acupressure.^7,13^ Two reviews included more than 1 intervention: acupressure and auricular acupressure,^10^ and massage therapy and acupressure.^15^

Although every review compared massage therapy with an active therapy comparator, 8 of 14 reviews also included sham/placebo as comparator. Some examples of active therapy are lifestyle advice,^6^ nutritional supplements,^9^ and artificial tears.^13^ With the exception of the review by Tan et al about the treatment of nausea and vomiting during pregnancy,^9^ all of these reviews had reported the combined effect of massage therapy compared to sham/placebo and active therapy comparators.

The included 14 reviews were categorized into the following 9 health conditions: sleep and mental health conditions in persons with cancer,^8,10^ dry eye disease,^13^ dementia,^12^ functional constipation,^6,7^ hypertension,^16^ kidney disease,^11,14,15^ post-burn pruritus,^17^ pregnancy,^9,18^ and pre-operative anxiety.^19^

Three reviews were mapped more than once.^10,11,15^ A review about acupressure as treatment for improving sleep quality in people with chronic kidney disease had 2 certainty of evidence conclusions.^11^ Bi et al conducted a review on efficacy of interventions on sleep quality in patients with cancer and included primary studies on acupressure as well as auricular acupressure.^10^ Natale et al included primary studies about massage therapy and acupressure as treatment for fatigue in dialysis patients.^15^

Figure 1 Evidence Map

Evidence map of conclusions from systematic reviews on massage therapy for non-painful adult health conditions. Reviews found either a potential benefit or no benefit compared to various comparison treatments, with varying levels of certainty in the evidence. Conclusions are categorized by certainty (high, moderate, low/very low) and visually coded by intervention type, comparator, and number of included studies.

Table 2 Certainty of Evidence Conclusions from Systematic Reviews Included in the Evidence Map

High Certainty of Evidence Conclusions (N = 1)
Author, Year | Condition | Certainty of Evidence Conclusion
Gu, 2023^6^ | Functional constipation | Compared to active therapy, usual care, and no treatment, abdominal massage therapy “[improved] constipation severity scores” and can “positively affect the quality of life of patients with constipation.””
Moderate Certainty of Evidence Conclusions (N = 4)
Author, Year | Condition | Certainty of Evidence Conclusion
Bi, 2023^10^ | Cancer (Sleep quality) | Compared to usual care, sham, and active therapy, acupressure “demonstrated significant effects in improving sleep quality” in patients with cancer.
Bi, 2023^10^ | Cancer (Sleep quality) | Compared to usual care, sham, and active therapy, auricular acupressure “demonstrated significant effects in improving sleep quality” in patients with cancer.
Natale, 2019^11^ | Chronic Kidney Disease (Sleep quality) | Compared with no acupressure, “acupressure probably slightly improved sleep latency [and] decreased fatigue” in people with chronic kidney disease.
Yin, 2024^12^ | Dementia (Depression) | “Massage plus [treatment as usual was] significantly more efficient than [treatment as usual] in reducing [Cornell Scale for Depression in Dementia] (CSDD).”

Three high-level observations can be made from the evidence mapping process for the potential benefit of massage therapy for some non-painful adult health conditions.

First, our search of systematic reviews published since 2018 identified 1 review describing a condition with high certainty of evidence and 3 reviews with moderate certainty of evidence of potential benefit of massage therapy. A high certainty of evidence conclusion was reported by Gu et al about functional constipation. They found abdominal massage therapy to improve constipation severity scores and quality of life when compared to active therapy or usual care. The 3 reviews with moderate certain of evidence were about acupressure and auricular acupressure as treatment for improving sleep quality in cancer patients,^10^ acupressure as treatment for improving sleep quality in chronic kidney disease patients,^11^ and massage therapy as treatment for depression in individuals living with dementia.^12^

Second, the majority of primary studies in included reviews compared massage therapy to routine or usual care. A handful of comparators were active therapies, such as artificial tears in a review about dry eye disease,^13^ and nutritional supplements in a review about nausea and vomiting during pregnancy.^9^

Third, half of the included reviews were focused on symptom improvements in specific conditions.^6,7,9,13,16–18^ The rest of the reviews focused on outcomes in specific populations. Two reviews focused on improving sleep quality in cancer patients10 and in people with chronic kidney disease.^11^ Two reviews described treatments for depression in individuals living with dementia^12^ and in patients with end stage renal disease.^14^ One review was about peri-operative anxiety, ^19^ 1 review was about fatigue in dialysis patients,^15^ and another review focused on health-related quality of life in cancer patients.^8^

### Adverse Events

Evidence about adverse events was collected by 7 of 14 ( 50%) reviews, with no serious adverse events reported. One review included certainty of evidence for adverse events.^7^

Jiang et al conducted a systematic review about the effect of auricular acupressure as treatment for functional constipation. The authors included 6 studies in a meta-analysis, which showed “[auricular acupressure] alone or in combination with other treatments was equally safe compared to other treatments.”^7^ The adverse reactions reported were “mostly minor, such as skin lesions or itching at the site of pressure, which typically resolved within a few days.”^7^ The certainty of evidence rating for adverse events in this review was low.

The other 6 reviews included details about adverse events.^9,11,13,15,16,19^ A Cochrane review by Natale et al about improving sleep quality in people with chronic kidney disease reported “no local skin reaction (eg, bruise) from repeated acupressure was reported during the study.”^11^ Another review by Natale et al on massage therapy and acupressure for fatigue in people with kidney failure requiring dialysis mentioned “adverse events were rarely and inconsistently reported.”^15^ Authors of a review about acupressure as treatment for dry eye disease noted that only 1 primary study had reported data on adverse events: “Only 2 participants in the intervention group experienced mild, pricking pain at the auricular acupuncture points.”^13^ A review about nausea and vomiting during pregnancy mentioned minor adverse events.^9^ Authors of a review about acupressure and pre-operative anxiety commented that “Given that only 2 trials specifically reported no adverse effects, it is inconclusive to show that acupressure is not associated with significant adverse effects.”^19^ In a review about acupressure and auricular acupressure as treatment to improve sleep quality in cancer patients, the authors included details about minor adverse events, such as “pain, fatigue and bruising caused by acupressure; allergic skin reactions caused by auricular acupressure.”^10^ The evidence table had further details: “Participants in both groups reported mild outer ear pain, discomfort, itchiness, and tenderness after seed placement” in a study of auricular acupressure compared to sham acupressure, and “participants reported mild severity adverse events, such as pain, tired” in a study of acupressure compared to sham acupressure.