# BACKGROUND

Massage therapy is a popular and widely accepted complementary and integrative health (CIH) modality for treatment of certain adult and pediatric health conditions.^1^ It is the practice of manual assessment and manipulation of the superficial soft tissues of skin, muscle, tendon, ligament, fascia, and the structures that lie within the superficial tissues for therapeutic purpose. Individuals may seek massage therapy to address a variety of conditions where conventional treatments may not always provide complete relief or may come with potential side effects.

Massage therapy has seen a dramatic increase in the number of users and visits since 2016 across the Veterans Health Administration (VHA). Massage therapy has been part of Veterans’ standard medical benefits package under VHA Directive 1137 since 2017.^2^ Veterans may utilize massage therapy and acupressure for a variety of reasons and conditions, including decreasing pain and increasing functionality. VHA stakeholders were interested in evidence for conditions other than pain condition; thus, we conducted a review and present an evidence map of massage therapy for non-painful adult health conditions.