# Appendix

## SEARCH STRATEGIES

### PUBMED (07/10/2018–12/31/2023)

# | Search Statement | Results
1 | (massag*[tiab] OR shiatsu[tiab] OR “myofascial”[tiab] OR acupressure*[tiab] OR Massage[Mesh] OR Acupressure[Mesh] OR “Myofascial Release Therapy”[Mesh]) | 21,753
2 | (systematic*[tiab] AND review[tiab]) OR “systematic overview*”[tiab] OR “Cochrane review*”[tiab] OR “systemic review*”[tiab] OR meta-analy*[tiab] OR metaanaly*[tiab] OR “meta analysis”[tiab] OR meta-review[tiab] OR meta-synthesis[tiab] OR “meta synthesis”[tiab] OR metasynthesis[tiab] OR “quantitative review”[tiab] OR “quantitative synthesis”[tiab] OR (meta-analytic*[tiab] AND review[tiab]) OR meta-analysis[pt] OR “systematic review”[pt] OR “systematic review*”[tiab] | 493,026
3 | #1 AND #2 | 1,535
4 | #3 AND ((2018/7/10:2023/12/31[pdat]) AND (english[Filter])) | 709

Search date: 07/10/2018–12/31/2023

### PUBMED (04/01/2023–07/19/2024)

# | Search Statement | Results
1 | (massag*[tiab] OR shiatsu[tiab] OR “myofascial”[tiab] OR acupressure*[tiab] OR Massage[Mesh] OR Acupressure[Mesh] OR “Myofascial Release Therapy”[Mesh]) | 23,231
2 | (systematic*[tiab] AND review[tiab]) OR “systematic overview*”[tiab] OR “Cochrane review*”[tiab] OR “systemic review*”[tiab] OR meta-analy*[tiab] OR metaanaly*[tiab] OR “meta analysis”[tiab] OR meta-review[tiab] OR meta-synthesis[tiab] OR “meta synthesis”[tiab] OR metasynthesis[tiab] OR “quantitative review”[tiab] OR “quantitative synthesis”[tiab] OR (meta-analytic*[tiab] AND review[tiab]) OR meta-analysis[pt] OR “systematic review”[pt] OR “systematic review*”[tiab] | 493,026
3 | #1 AND #2 | 1,773
4 | #3 AND ((2023/4/01:2024/12/31[pdat]) AND (english[Filter])) | 274

Search date: 04/01/2023–07/19/2024

### CINAHL (07/10/2018–12/31/2023)

# | Search Statement | Results
1 | ((TI massag* OR AB massag*) OR (TI shiatsu OR AB shiatsu) OR (TI myofascial OR AB myofascial) OR (TI acupressure* OR AB acupressure*) OR (MH “Massage+”) OR (MH Acupressure+) OR (MH “Myofascial Release”)) | 27,699
2 | ((TI systematic* OR AB systematic*) AND (TI review OR AB review)) OR (TI “systematic overview*” OR AB “systematic overview*”) OR (TI “Cochrane review*” OR AB “Cochrane review*”) OR (TI “systemic review*” OR AB “systemic review*”) OR (TI meta-analy* OR AB meta-analy*) OR (TI metaanaly* OR AB metaanaly*) OR (TI “meta analysis” OR AB “meta analysis”) OR (TI meta-review OR AB meta-review) OR (TI meta-synthesis OR AB meta-synthesis) OR (TI “meta synthesis” OR AB “meta synthesis”) OR (TI metasynthesis OR AB metasynthesis) OR (TI “quantitative review” OR AB “quantitative review”) OR (TI “quantitative synthesis” OR AB “quantitative synthesis”) OR ((TI meta-analytic* OR AB meta-analytic*) AND (TI review OR AB review)) OR (TI “systematic review*” OR AB “systematic review*”) OR (MH “Systematic Review”) | 242,119
3 | #1 AND #2 | 590
4 | #3; Filters: 07/2018 – 12/2023; English; Academic Journals | 555

Search date: 07/10/2018–12/31/2023

### CINAHL (04/01/2023–07/19/2024)

# | Search Statement | Results
1 | ((TI massag* OR AB massag*) OR (TI shiatsu OR AB shiatsu) OR (TI myofascial OR AB myofascial) OR (TI acupressure* OR AB acupressure*) OR (MH “Massage+”) OR (MH Acupressure+) OR (MH “Myofascial Release”)) | 24,975
2 | ((TI systematic* OR AB systematic*) AND (TI review OR AB review)) OR (TI “systematic overview*” OR AB “systematic overview*”) OR (TI “Cochrane review*” OR AB “Cochrane review*”) OR (TI “systemic review*” OR AB “systemic review*”) OR (TI meta-analy* OR AB meta-analy*) OR (TI metaanaly* OR AB metaanaly*) OR (TI “meta analysis” OR AB “meta analysis”) OR (TI meta-review OR AB meta-review) OR (TI meta-synthesis OR AB meta-synthesis) OR (TI “meta synthesis” OR AB “meta synthesis”) OR (TI metasynthesis OR AB metasynthesis) OR (TI “quantitative review” OR AB “quantitative review”) OR (TI “quantitative synthesis” OR AB “quantitative synthesis”) OR ((TI meta-analytic* OR AB meta-analytic*) AND (TI review OR AB review)) OR (TI “systematic review*” OR AB “systematic review*”) OR (MH “Systematic Review”) | 267,015
3 | S1 AND S2 | 1,434
4 | S3; Filters: 04/2023 – 12/2024; English; Academic Journals | 123

Search date: 04/01/2023–07/19/2024

### COCHRANE DATABASE OF SYSTEMATIC REVIEWS (07/10/2018–12/31/2023)

# | Search Statement | Results
1 | ((massag* OR shiatsu OR myofascial OR acupressure*):ti,ab OR [mh Massage] OR [mh Acupressure] OR [mh “Myofascial Release Therapy”]) | 10,681
2 | #1; Filters: 07/2018 – 12/2023; Excluding Trials (10,553) | 36

Search date: 07/10/2018–12/31/2023

### COCHRANE DATABASE OF SYSTEMATIC REVIEWS (04/01/2023–07/19/2024)

# | Search Statement | Results
1 | ((massag* OR shiatsu OR myofascial OR acupressure*):ti,ab OR [mh Massage] OR [mh Acupressure] OR [mh “Myofascial Release Therapy”]) | 12,406
2 | #1; Filters: 04/2023 – 12/2024; Excluding Trials (12,275) | 8

Search date: 04/01/2023–07/19/2024

### WEB OF SCIENCE (07/10/2018–12/31/2023)

# | Search Statement | Results
1 | (TS=massag* OR TS=shiatsu OR TS=myofascial OR TS=acupressure*) | 18,433
2 | ((TI=systematic* OR AB=systematic*) AND (TI=review OR AB=review)) OR (TI=“systematic overview*” OR AB=“systematic overview*”) OR (TI=“Cochrane review*” OR AB=“Cochrane review*”) OR (TI=“systemic review*” OR AB=“systemic review*”) OR (TI=meta-analy* OR AB=meta-analy*) OR (TI=metaanaly* OR AB=metaanaly*) OR (TI=“meta analysis” OR AB=“meta analysis”) OR (TI=meta-review OR AB=meta-review) OR (TI=meta-synthesis OR AB=meta-synthesis) OR (TI=“meta synthesis” OR AB=“meta synthesis”) OR (TI=metasynthesis OR AB=metasynthesis) OR (TI=“quantitative review” OR AB=“quantitative review”) OR (TI=“quantitative synthesis” OR AB=“quantitative synthesis”) OR ((TI=meta-analytic* OR AB=meta-analytic*) AND (TI=review OR AB=review)) OR (TI=“systematic review*” OR AB=“systematic review*”) | 561,467
3 | #1 AND #2 | 1,683
4 | #3; Filters: 2018–2023; English | 960

Search date: 07/10/2018–12/31/2023

### WEB OF SCIENCE (04/01/2023–07/19/2024)

# | Search Statement | Results
1 | (TS=massag* OR TS=shiatsu OR TS=myofascial OR TS=acupressure*) | 20,467
2 | ((TI=systematic* OR AB=systematic*) AND (TI=review OR AB=review)) OR (TI=“systematic overview*” OR AB=“systematic overview*”) OR (TI=“Cochrane review*” OR AB=“Cochrane review*”) OR (TI=“systemic review*” OR AB=“systemic review*”) OR (TI=meta-analy* OR AB=meta-analy*) OR (TI=metaanaly* OR AB=metaanaly*) OR (TI=“meta analysis” OR AB=“meta analysis”) OR (TI=meta-review OR AB=meta-review) OR (TI=meta-synthesis OR AB=meta-synthesis) OR (TI=“meta synthesis” OR AB=“meta synthesis”) OR (TI=metasynthesis OR AB=metasynthesis) OR (TI=“quantitative review” OR AB=“quantitative review”) OR (TI=“quantitative synthesis” OR AB=“quantitative synthesis”) OR ((TI=meta-analytic* OR AB=meta-analytic*) AND (TI=review OR AB=review)) OR (TI=“systematic review*” OR AB=“systematic review*”) | 666,519
3 | #1 AND #2 | 2,005
4 | #3; Filters: 2023–2024; English; Review Article, Article, Early Access | 357

Search date: 04/01/2023–07/19/2024

### AMED (07/10/2018–12/31/2023)

# | Search Statement | Results
1 | ((TI massag* OR AB massag*) OR (TI shiatsu OR AB shiatsu) OR (TI myofascial OR AB myofascial) OR (TI acupressure* OR AB acupressure*) OR (DE “MASSAGE”) OR (DE “ACUPRESSURE”)) | 4,920
2 | ((TI systematic* OR AB systematic*) AND (TI review OR AB review)) OR (TI “systematic overview*” OR AB “systematic overview*”) OR (TI “Cochrane review*” OR AB “Cochrane review*”) OR (TI “systemic review*” OR AB “systemic review*”) OR (TI meta-analy* OR AB meta-analy*) OR (TI metaanaly* OR AB metaanaly*) OR (TI “meta analysis” OR AB “meta analysis”) OR (TI meta-review OR AB meta-review) OR (TI meta-synthesis OR AB meta-synthesis) OR (TI “meta synthesis” OR AB “meta synthesis”) OR (TI metasynthesis OR AB metasynthesis) OR (TI “quantitative review” OR AB “quantitative review”) OR (TI “quantitative synthesis” OR AB “quantitative synthesis”) OR ((TI meta-analytic* OR AB meta-analytic*) AND (TI review OR AB review)) OR (TI “systematic review*” OR AB “systematic review*”) | 8,613
3 | #1 AND #2 | 223
4 | #3; Filters: 07/2018 – 12/2022; English; Academic Journals | 81

Search date: 07/10/2018–12/31/2023

### AMED (04/01/2023–07/19/2024)

# | Search Statement | Results
1 | ((TI massag* OR AB massag*) OR (TI shiatsu OR AB shiatsu) OR (TI myofascial OR AB myofascial) OR (TI acupressure* OR AB acupressure*) OR (DE “MASSAGE”) OR (DE “ACUPRESSURE”)) | 5,037
2 | (((TI systematic* OR AB systematic*) AND (TI review OR AB review)) OR (TI “systematic overview*” OR AB “systematic overview*”) OR (TI “Cochrane review*” OR AB “Cochrane review*”) OR (TI “systemic review*” OR AB “systemic review*”) OR (TI meta-analy* OR AB meta-analy*) OR (TI metaanaly* OR AB metaanaly*) OR (TI “meta analysis” OR AB “meta analysis”) OR (TI meta-review OR AB meta-review) OR (TI meta-synthesis OR AB meta-synthesis) OR (TI “meta synthesis” OR AB “meta synthesis”) OR (TI metasynthesis OR AB metasynthesis) OR (TI “quantitative review” OR AB “quantitative review”) OR (TI “quantitative synthesis” OR AB “quantitative synthesis”) OR ((TI meta-analytic* OR AB meta-analytic*) AND (TI review OR AB review)) OR (TI “systematic review*” OR AB “systematic review*”) | 9,088
3 | #1 AND #2 | 237
4 | S3; Filters: 04/2023 – 12/2024; English; Academic Journals | 1
| Total | 2830
| Total after deduplication | 1563

Search date: 04/01/2023–07/19/2024