# ABBREVIATIONS TABLE

Abbreviation: Definition
AHRQ: Agency for Healthcare Research and Quality
AMED: Allied and Complementary Medicine Database
CDSR: Cochrane Database of Systematic Reviews
CIH: Complementary and integrative health
CINAHL: Cumulated Index to Nursing and Allied Health Literature
CINeMA: Confidence in Network Meta-Analysis
EPC: Evidence-based Practice Center
GRADE: Grading of Recommendations, Assessment, Development and Evaluations