# Supplementary Materials

- Characteristics Include Studies (XLSX)
- Certainty of Evidence (SRs) (XLSX)
- Excluded Studies (XLSX)
- Peer Review Feedback (XLSX)

## VA Related Documents

Supplementary Materials (XLSX)