# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE FOR KEY QUESTIONS 1 AND 2

Most articles examining social determinants of health in Veterans and non-Veterans addressed standard sociodemographics, such as education, marital status, income, and employment. Fewer articles addressed other social determinants, including those that were high priority for our operational partners.

Included articles that examined rural residence had wide variation in the definition of rurality, limiting interpretations. However, most articles used nationally representative data and were consistent in reporting little or no differences in proportions of Veterans and non-Veterans who lived in rural settings. Thus, we found moderate strength evidence of no substantial differences in rurality between Veterans and non-Veterans. In contrast, we found insufficient evidence on the effects of rurality on differences in health services utilization, health behaviors, or health outcomes between Veterans and non-Veterans. We identified only 5 articles that pertained to these important questions, and these articles varied in data sources, participant demographics, measures of rurality, analytic strategies, and outcomes examined.

Included articles on trauma examined a wide variety of exposures, including type, timing, and measures used. Overall, we found low strength evidence that there is higher prevalence of trauma exposure among Veterans, as compared with non-Veterans. We found low strength evidence that trauma exposure contributes to differences in prevalence of smoking between Veterans and non-Veterans. While several articles examined these associations,^27,34,70^ only one reported testing for statistical significance of moderating effects (ie, interaction between Veteran status and trauma exposure in predicting smoking).^70^ Results from all 3 articles supported an increased effect of trauma in non-Veterans in predicting smoking. Thus, there were consistent associations of current smoking with prior trauma exposure, regardless of whether the type of trauma being assessed was childhood adversity, adult sexual trauma, or physical trauma. In addition, one article also found that childhood adversity mediated associations between Veteran status and smoking and between Veteran status and disability.

Only 2 articles addressed sexual orientation for Veterans and non-Veterans. These included only women, had very different demographics (eg, age), and small numbers reporting minority sexual orientation. While one article found a higher proportion of women Veterans identifying as sexual minorities, the other article reported no differences. Thus, we found insufficient evidence on whether there are differences in prevalence of sexual minorities between Veterans and non-Veterans. Only one article assessed the role of sexual minority status on health outcomes, and while it found independent associations between sexual orientation and mortality, the analyses did not examine whether sexual minority status accounted for differences in mortality between Veterans and non-Veterans.

## SUMMARY OF EVIDENCE FOR KEY QUESTIONS 3 AND 4

Most articles examining social determinants of health in engaged and non-engaged Veterans included standard sociodemographics, such as education, marital status, income, and employment. Very few articles addressed other social determinants, and we found none that investigated sexual orientation, gender identity, or financial barriers to health care.

Similar to articles that examined rurality among Veterans and non-Veterans, variation in the definition of rurality and participant demographics limit interpretations. However, most articles were consistent in reporting little or no differences in proportions of engaged and non-engaged Veterans who lived in rural settings. We found moderate strength evidence of no substantial differences in rurality between engaged and non-engaged Veterans, but for certain specific services (eg, VHA homeless services), there may be differences in proportion with rural residence. We found insufficient evidence on the effects of rurality on differences in health services utilization, health behaviors, or health outcomes between engaged and non-engaged Veterans. We found only 3 articles that were applicable to any of these questions, and there was variation in data sources, participant demographics, measures of rurality, analytic strategies, and outcomes examined.

Articles addressing trauma exposure for engaged and non-engaged Veterans also examined many types of trauma experienced over different time periods. Overall, we found low strength evidence that there is increased trauma exposure for engaged Veterans, as compared with non-engaged Veterans. Most articles found higher levels of trauma reported among engaged Veterans, compared with non-engaged Veterans, but they were of low or moderate quality.

We identified no articles that addressed the role of trauma exposure in differences in health services access, health behaviors, or health outcomes between engaged and non-engaged Veterans. Similarly, we found no articles that examined sexual orientation or gender identity for engaged and non-engaged Veterans.

## LIMITATIONS

We provide an evidence map and qualitative syntheses of results from a subset of articles which addressed high-priority social determinants for our VHA partners. Evidence maps are designed to give a broad overview of the evidence base rather than provide in-depth data analyses and outcome summary estimates. Results from evidence maps are best used to describe areas where research has been conducted and where major gaps exist. Articles were excluded if they did not compare the populations of interest (ie, Veteran/non-Veteran, engaged/non-engaged), as it was beyond the scope of this work to compare results for these groups when presented in separate studies. Thus, lack of evidence for any given social determinant and outcome of interest speaks only to whether published studies compared the impacts of social determinants for our groups of interest, and our results do not imply that evidence is lacking for effects of social determinants on health overall or within each of these populations. We limited quality assessment to included articles that examined at least one of the 3 high-priority social determinants (rurality, trauma, and sexual orientation or gender identity). Publication bias may have affected our results if articles were less likely to be published if they found no evidence of differences in social determinants or lack of a role for social determinants on health behaviors, health access, or health outcomes. We acknowledge some variation in defining Veteran status, particularly for articles using data from large national cohorts of the general US population. These cohorts used slightly different questions in describing service in the military (eg, US armed forces instead of US military) but were very similar in general. Some excluded individuals in active service (eg, NHIS), while others obtained more information about current vs past service (eg, BRFSS). WHI was the only dataset that had a time criterion (ie, 180 days of active service) for qualifying as a Veteran. Finally, although we aimed to be broad and inclusive in addressing social determinants of health, we needed to limit the scope and therefore focused our search on social determinants with available measures and of high interest to our VHA partners.

## APPLICABILITY AND IMPLICATIONS FOR POLICY AND PRACTICE

Our evidence review directly contributes to several essential strategies for improving VHA services and enhancing Veteran health, as outlined in the Blueprint for Excellence.^143^ For example, the first essential strategy seeks to meet the needs of the most vulnerable Veterans, including those with low socioeconomic status. Other strategies emphasize the personalization of care and promote the delivery of patient-centered care, which requires understanding the contribution of social determinants, particularly regarding implications for tailoring and targeting of VHA services. Our evidence review has demonstrated that the evidence base for social determinants of Veterans health largely mirrors what is known about the general population. Namely, there is a large body of evidence addressing classic socioeconomic factors, but there is a lack of evidence about more recently developed and conceptualized social determinants, such as trauma exposures, sexual orientation, and gender identity. The policy implication of this result is to support development and implementation of consistent, accurate measures of these social determinants for Veterans. This would enable future work to understand the effects of such social determinants on health behaviors, health services utilization, and health outcomes.

In areas where we did not identify sufficient evidence that examined the differential impact of certain social determinants (eg, rurality) on our outcomes of interest, for either Veterans compared with non-Veterans or for engaged and non-engaged Veterans, our evidence review provides indirect support for policies that apply knowledge of the effects of these social determinants in the general US population. For example, both Veterans and non-Veterans, and engaged and non-engaged Veterans appear similar in proportions residing in rural settings, and thus, it would be reasonable to use information about challenges to health and health care in rural US communities, to help direct VHA policies addressing health care access for Veterans in rural settings.

In contrast, we found some evidence that trauma exposures may be different between Veterans and non-Veterans, and between engaged and non-engaged Veterans, suggesting that understanding the impacts of trauma on health care utilization and outcomes could help inform VHA policies for current and future service needs. This also highlights the importance of establishing consistent, accurate, and meaningful measures of trauma exposure in VHA data systems, in order to improve outcomes for Veterans now and in the future.

## RESEARCH GAPS/FUTURE RESEARCH

This evidence review represents an extensive and thorough examination of available sources of evidence to address the role of a variety of social determinant. In addition to systematic searches of large databases of published articles, we also examined grey literature (eg, white papers) associated with nationally representative cohorts and large VA research studies and programs. Because we found no additional substantial contribution from the grey literature, our review provides a guide to the existing peer-reviewed scientific literature that address a variety of important social determinants. Thus, this work enables future evaluations and syntheses of the evidence supporting the role of social determinants in health, beyond the 3 high-priority determinants that we examined in detail. Another important contribution of this evidence review is to identify major gaps in clinical evidence and guide future research to improve care quality, delivery, and policy. The first major evidence gap is the lack of articles that addressed certain social determinants, such as gender identity; the evidence gap is even greater with regard to the role of social determinants in health care access, health behaviors, and health outcomes. In the context of our main goals to understand social determinants for Veterans and non-Veterans, and engaged and non-engaged Veterans, the ability to conduct research and generate evidence depends on whether these determinants are being assessed by national studies that also characterize Veteran status, or Veteran utilization of and engagement with VHA services. Thus, some of the areas which lack published articles would greatly benefit from inclusion of consistent measures of social determinants and military experience. To that end, it may be easiest to promote the addition of assessments for certain social determinants (eg, sexual orientation) to existing national studies that already collect information about Veterans (eg, American Community Surveys). To address lack of evidence for social determinants affecting health of Veterans engaged and not engaged in VHA services, we need data sources that provide information on social determinants and non-VHA health care access and utilization for both engaged and non-engaged Veterans. Included articles that examined social determinants have largely used VHA data, in combination with other administrative or health data collected for a limited group (eg, Medicare patients or Indian Health Service).

In addition to the major gaps related to lack of existing data, our evidence review brought to light several challenges to understanding the role of social determinants, even when there are published studies. First, in our detailed review of rurality and trauma, we found that measurement diversity led to inconsistent results and interpretation challenges. Past work has also shown that rurality measure variability leads to substantially different estimates of rural residence among Veterans engaged in VHA care.^144^ Moreover, measures for both rurality and trauma actually encompass conceptually related but distinct aspects within these broader constructs. Rural communities are not just defined by distance and/or population density, but also by social connections, cultural norms, and attitudes.^145^ As we seek to understand the mechanism by which rural Veterans may experience worse health outcomes, so that we can improve those outcomes, we need direct measures of the aspects of rural communities that matter for health. Similarly, although a variety of adverse circumstances and traumatic events could all plausibly affect Veterans' health, if we fail to make conceptually important distinctions between types of trauma, then it will be harder to clearly define relationships and target pathways for improving health outcomes.

Second, it is important to consider that the relationships between Veteran experiences and social determinants are likely bidirectional and dynamic over the lifespan (Figure 1). One example of these complex relationships is with educational status, where education can affect selection into the military and being a Veteran could in turn impact educational attainment (either in the military or after military service).^146^ In the modern era of military service without conscription, social determinants may have even stronger effects on who joins the military and their military experiences. For example, one trauma article examined this potential complexity by carefully accounting for differences between “draft era” Veterans and “all volunteer era” Veterans.^22^ In adjusted analyses using BRFSS data, this article found that the number of ACEs was significantly different between Veterans and non-Veterans in the “all volunteer” period (p<0.001) but not in the draft era (p=0.96). The article also stratified analyses by men and women, finding that the differences in trauma results between these different time periods were mainly in men (who could be drafted before 1973), but not in women (who were never eligible for conscription). For rurality, it may be that both rural residence in childhood and current rural residence are important for health, but not in the same ways.

Third, a major challenge in this field is to accurately and efficiently identify literature that addresses the questions posed. To refine our scope, we devoted extensive effort to develop conceptual and analytic frameworks to better understand and define the roles of social determinants as they might differentially vary in prevalence or impact among Veterans versus non-Veterans and engaged versus non-engaged Veterans. We used broad search terms to query several databases, and we examined multiple sources of “gray literature.” We searched and screened over 8000 citations, and less than 2% met eligibility criteria. Many studies assessed social determinants but did not provide information on the independent and differential effect or prevalence of social determinants in the populations of interest. We encourage others to review our conceptual and analytic frameworks and provide suggestions for future refinement. Having clear conceptualizations of how social determinants may affect health is central for developing knowledge of causal pathways and understanding the independent role of social determinants in health, healthcare delivery, and healthcare policy for Veterans.

While longitudinal and nationally representative cohort studies would be the ideal design for examining the complex interplay of social determinants of health and Veteran experiences, conceptually clear and innovative analyses of cross-sectional data also have the potential to substantially advance our understanding. Such analyses should address potential selection effects of social determinants and other mechanisms that predate military service, as well as social determinants that are affected by Veteran experiences and may mediate the differences in health after those experiences. To support such work, we need multidisciplinary teams that include content and methodologic experts in the diversity of social determinants, as well as investigators with experience in clinical, operational, and policy settings.

### Summary of Major Research Gaps and Recommendations

- Promote inclusion of consistent and accurate assessments of high-priority social determinants (eg, trauma exposures, sexual orientation) for existing or ongoing national datasets that also capture Veteran status.
- Develop new data sources and/or improve ability to link with existing non-VHA data sources, in order to address social determinants and outcomes for Veterans engaged and not engaged in VHA services or benefits.
- Apply measures of social determinants more consistently and whenever possible, provide sufficient detail to address how social determinants may be affecting outcomes.
- Develop and utilize clear conceptual frameworks that guide analytic decisions and interpretation of results.

## CONCLUSIONS

While extensive literature addresses education, marital status, income, and/or employment, little published work exists on other social determinants of health (eg, trauma and sexual orientation). We found no differences in rural residence between Veterans and non-Veterans, and between engaged and non-engaged Veterans. Trauma exposure among Veterans was higher in engaged versus non-engaged Veterans. We found insufficient evidence to determine if there are differences in sexual orientation or gender identity between Veterans and non-Veterans or between engaged and non-engaged Veterans. Social determinant knowledge gaps could be addressed by clear conceptual frameworks and innovative analytic strategies, even if limited by using cross-sectional data. Direct standardized measurement of key community characteristics of rural settings and focused assessment of specific types of trauma may be more informative for defining pathways that could be targeted for improving the health of Veterans.