# RESULTS

We searched 4 databases and screened over 7000 abstracts to identify 131 articles that addressed at least one of the 4 key questions (Figure 4).^11,13-142^ We provide evidence maps, followed by qualitative syntheses of results for the 3 high-priority social determinants—rurality, history of trauma, and sexual orientation or gender identity. We first describe the evidence map and qualitative synthesis for Veterans and non-Veterans (ie, Key Questions 1 and 2), followed by results for Veterans engaged and not engaged in various VHA services and benefits (ie, Key Questions 3 and 4).

Figure 4 Citation Screening and Selection of Included Articles

a Total includes an additional 3 articles found through an expedited review of MEDLINE citations (N=354) found using same search terms except limited to trials, 1 article found through review of publications from the VA Epidemiology Program, and 2 articles recommended by expert reviewers.

## KEY QUESTIONS 1 AND 2 How do Veterans compare to non-Veterans in prevalence and characteristics of social determinants of health? Does variation in social determinants of health account for differences in health services access, health behaviors, and health outcomes between Veterans and non-Veterans?

### Key Messages

- Most articles examining social determinants of health in Veterans included standard sociodemographics, such as education, marital status, income, and employment.
- There are no substantial differences in proportions of Veterans and non-Veterans who lived in rural settings. Most articles used nationally representative data and were consistent in their results, but rurality definitions varied widely, thus limiting interpretations. (Moderate strength evidence)
- We found insufficient evidence on the effects of rurality on health services utilization, health behaviors, or health outcomes between Veterans and non-Veterans.
- There is higher prevalence of trauma exposure among Veterans, compared with non-Veterans. Half of the articles used nationally representative data, results were somewhat inconsistent, and trauma types and measures varied across articles. (Low strength of evidence)
- Trauma exposure contributes to differences in the smoking prevalence between Veterans and non-Veterans. (Low strength of evidence)
- We found insufficient evidence on whether prevalence differences exist in minority sexual orientation between Veterans and non-Veterans.
- We found insufficient evidence that sexual minority status accounts for mortality differences between Veteran and non-Veteran women.
- No included articles addressed gender identity in comparing Veterans and non-Veterans.

### Evidence Map

We identified 99 articles which addressed at least one social determinant of interest for Veterans and non-Veterans. The vast majority of articles used cross-sectional data and included over 1000 participants (Appendix C, Table 1). Education, marital status, income, and employment were addressed by the greatest number of articles, and some of these articles examined the role of these social determinants in health behaviors, health services access or utilization, and/or health outcomes (Figure 5 and Appendix C, Table 1). In contrast, other social determinants were addressed by far fewer articles, and several social determinants were not examined by any articles which considered health behaviors, or health services access or utilization (Figure 5). We found no articles addressing gender identity for Veterans and non-Veterans.

Figure 5 Summary of Included Articles Addressing Social Determinants and Various Outcomes for Veterans and non-Veteransa^a^ a Shading in a cell represents the number of articles; rows are social determinants of interest and columns are for total number of eligible articles followed by number of eligible article reporting a health-related outcome of interest

### Qualitative Synthesis of Results for Rurality, Trauma, and Sexual Orientation and Gender Identity for Veterans and Non-Veterans

We identified 11 articles which examined rurality, 11 which addressed trauma, and 2 on sexual orientation for Veterans and non-Veterans. Most articles on rurality, trauma, and/or sexual orientation used nationally representative datasets, included more than 5000 participants, and were rated low or medium quality (Table 2). One-third of articles included data on only men, and 5 had only women participants. Half of the articles investigated the role of rurality, trauma, and/or sexual orientation in health behaviors, health services access or utilization, or various health outcomes. Detailed results from included articles are provided in Appendix C, Table 2 and described below.

Table 2 Characteristics of Included Articles for Rurality, Trauma, and Sexual Orientation—Veterans and Non-Veterans

| Rurality^a^ | Trauma | Sexual Orientation
Total number of articles | 11 | 11 | 2
Nationally representative dataset | 9 | 6 | 2
Exclusively men | 5 | 3 | —
Exclusively women | — | 4 | 2
Number of participants:
100-1000 | 1 | 3 | —
1001-5000 | 4 | 3 | 1
>5000 | 6 | 5 | 1
Quality:
Low | 3 | 6 | —
Medium | 7 | 4 | 2
High | 1 | 1 | —
Examined role of social determinant in:
Health behaviors | — | 4 | —
Health services access or utilization | 2 | — | —
Mental health | 2 | 4 | —
General health | 1 | 1 | —
Mortality | — | 1 | 1
Other health outcomes | 1 | 2 | —

a Number of participants unclear in one study (Ajmera 2011^14^); articles may be included in more than one category

#### Rurality

Articles that examined rurality were all rated medium or low quality. Articles used a variety of measures, including Metropolitan Statistical Areas (MSA),^14,92,99,130,132,142^ self-reported rural/urban residence,^26,63,69^ and Rural-Urban Continuum (RUC) codes^129^ (Appendix C, Table 2). There were generally no differences in the proportion of rural residence between Veterans and non-Veterans, although actual prevalence estimates were highly variable (eg, range 18-47% of Veterans had rural or non-metropolitan residences). This was likely due to variation in rurality definition, participant demographics (eg, age and sex), and years of datasets used (range 1986-2012). For example, one article used self-reported rural versus urban residence from a national Pew Center survey in 2008 and found 18% of Veterans and 16% of non-Veterans were “rural”.^63^ Another article using 2000 BRFSS data defined “non-metropolitan” residence by RUC codes 4-9, and reported 25% of Veterans and 22% of non-Veterans were in this category.^129^

Only 3 articles investigated the role of rurality in health outcomes,^99,129,132^ all were of medium quality, and none found significant effects for either Veteran status or rurality (Appendix C, Table 2). Of 2 articles examining the association of rurality with health services access or utilization, one reported no substantial difference between metropolitan and non-metropolitan participants in proportion having a “checkup” within prior 2 years.^129^ The other article found significant interaction effects between rural residence and a combined Veteran/VHA user categorical variable (ie, non-Veteran, Veteran VHA user, and Veteran non-VHA user), when examining associations with total healthcare expenditures, but did not report the magnitude of the interaction effects.^130^ Both of these articles were medium quality.

#### Trauma

Of 11 articles examining trauma exposures between Veterans and non-Veterans, only one was rated as high quality,^82^ and 5 were rated as medium quality.^22,27,34,70,93^ Articles examining trauma assessed a variety of trauma types, using different measures, with little consistency across studies. Adverse childhood experiences were examined in 6 articles comparing Veterans and non-Veterans,^22,53,70,93,96,111,137^ with the Adverse Childhood Experiences scale (ACEs) being the most commonly used measure.^22,70,93^ This is possibly because the ACEs module was included in BRFSS, which was the data source used in 3 of these articles. One article reported only whether respondents had been “victimized” in the prior 12 months.^131^ Adult experience of sexual trauma or intimate partner violence (IPV) was examined in 4 articles comparing Veterans and non-Veterans.^27,53,96,111^ Adult experience of physical trauma was examined in 2 articles comparing Veterans and non-Veterans.^82,96^ Combat-related trauma was examined in one article comparing Veterans and non-Veterans (assessed in Veterans only).^96^

Prevalence estimates were inconsistent across articles comparing Veterans and non-Veterans with 6 finding higher prevalence among Veterans,^22,34,70,96,111,131^ 3 finding higher prevalence among non-Veterans,^27,53,82^ and 2 finding no difference in prevalence between Veterans and non-Veterans.^93,137^ Inconsistencies may be due to a broad range of historical periods and cohorts being studied (ie, Vietnam era through OIF/OEF, Appendix C, Table 2). Furthermore, comparison groups of Veterans and non-Veterans often differed in composition with respect to age, sex, race/ethnicity, and other key characteristics. There were also very narrow groups targeted in certain articles (eg, homeless smokers only).^53^

Only 4 articles examined associations of trauma exposure with health behaviors, and all focused on current smoking and binge or heavy drinking.^27,34,70,93^ Trauma exposure was associated with higher prevalence of current smoking, with 2 of these articles examining adult trauma exposure (IPV) and 2 examining childhood trauma exposure (ACEs). Only one of the 4 articles also found a positive association between trauma exposure (ACEs) and binge-drinking.^70^ Three of these articles^27,34,70^ analyzed trauma exposure as a moderating variable between Veteran status and health behaviors (ie, something that potentially changes the strength or direction of association between Veteran status and health behaviors). Of these, 2 did not examine the statistical significance of moderating effects, and the remaining article^70^ assessed both smoking (ever smoked) and binge drinking, finding that there were significant interaction effects between Veteran status and ACEs score on having ever smoked (stratified results for women Veterans odds ratio [OR] 1.07 [95% CI 1.03, 1.12] vs women non-Veterans OR 1.14 [95% CI 1.13, 1.15], and comparisons for men, Veterans OR 1.06 [95% CI 1.05, 1.07] vs non-Veterans OR 1.12 [95% CI 1.11, 1.13]). There were no significant interaction effects between Veteran status and trauma exposure (ACEs) in predicting likelihood of binge drinking. Only one article^93^ considered whether trauma exposure might be a mediating variable between Veteran status and health risk behaviors (ie, something that might account for the relationship between Veteran status and the health risk behavior). In this article, after adjusting for age, race/ethnicity, education, income, and partnership status, Veterans had a higher OR for current smoking vs non-Veterans (1.84 [95% CI 1.18, 2.88]). After further adjusting for ACEs score, the OR associated with Veteran status was no longer significant (1.57 [95% CI 0.96, 2.58]), suggesting that adverse childhood experiences may explain some of the higher prevalence of current smoking associated with Veteran status.

Five articles examined associations of trauma exposure with a range of health outcomes.^27,34,70,82,93^ Several articles found that trauma exposure was positively associated with higher risk for adverse health outcomes. One article found that ACEs scores were associated with poorer health-related quality of life among both males and females, with RRs consistently higher among non-Veterans, compared with Veterans.^70^ One article examined trauma exposure as a mediating factor in associations between Veteran status and diabetes, cardiovascular events, asthma, and disability.^93^ Veteran status was only significantly associated with disability outcome—adjusted OR 1.83 (95% CI 1.08, 3.10) with covariates including age, race/ethnicity, education, income, and partnership status.^93^ After adding ACEs score, the OR for Veteran status was no longer significant (1.57 [95% CI 0.90, 2.75]), suggesting that adverse childhood experiences may account for some part of the higher prevalence of disability among Veterans compared with non-Veterans. Two articles employed BRFSS data to examine associations of IPV with depressive symptoms.^27,34^ One reported unadjusted estimates of depressive symptoms comparing Veterans and non-Veterans, with stratification by IPV.^34^ There were no differences for those who reported no IPV (7% vs 7% for Veterans vs non-Veterans), but among those reporting IPV, depressive symptoms were less prevalent among Veterans than non-Veterans (13% vs 25%, p < 0.01).^34^ The second article used both stratified and adjusted analyses, finding broadly similar results, with IPV being associated with higher odds of having depressive symptoms among Veterans (2.63 [95% CI 1.49, 4.65]), and among non-Veterans (4.37 [95% CI 2.79, 6.86]).^27^ In the article examining all-cause mortality as the outcome, HRs were significantly higher for certain types of trauma in certain groups but not others; for example, higher HR associated with exposure to physical abuse among heterosexual non-Veterans (1.17 [95% CI 1.02, 1.33]), and higher HR associated with “other trauma” among sexual-minority Veterans (4.31 [95% CI 1.38, 3.47]), but not among other sub-groups.^82^ Verbal abuse was not associated with all-cause mortality in any of the 4 sub-groups assessed.^82^

#### Sexual Orientation

Both articles examining sexual orientation used nationally representative data, had only women participants, and were rated medium quality (Appendix C, Table 2).^80,82^ One article used data from the Women's Health Initiative (WHI) and found a higher proportion of women Veterans identified as sexual minorities (ie, non-heterosexual) compared to women non-Veterans (4% vs 1%).^82^ The other article used NHANES data (1999-2010) and reported no significant difference in prevalence of non-heterosexual orientation (7% among Veterans, 5% for non-Veterans).^80^ The 2 study populations differed in age (mean age 63 years in the WHI study and 40 years in the NHANES study) and race/ethnicity (85% non-Hispanic white in WHI study and 70% in the NHANES study).

The article using WHI data found that sexual minority status (HR 1.20 [95%CI 1.07, 1.36]) and Veteran status (HR 1.14 [95%CI 1.06, 1.22]) were independently associated with increased risk for all-cause mortality in adjusted analyses.^82^ Authors examined interaction effects between sexual minority status and Veteran status for predicting risk of all-cause mortality, cancer-specific mortality, and cardiovascular disease-related mortality; there were no significant interactions in any of the models for all-cause or cardiovascular mortality, and some inconsistent interaction effects in models evaluating risk for cancer mortality (significant in only half of models).

## KEY QUESTIONS 3 AND 4 How do engaged (ie, enrolled in or utilizing categories of VHA services or benefits) Veterans compare to non-engaged (ie, not enrolled in or utilizing VHA services or benefits) Veterans in prevalence and characteristics of social determinants of health? Does variation in social determinants of health account for differences in health services access, health-related behaviors, and health outcomes between engaged Veterans and non-engaged Veterans?

### Key Messages:

- Most articles examining social determinants of health in engaged and non-engaged Veterans included standard sociodemographics, such as education, marital status, income, and employment.
- There were no substantial differences in rurality between engaged and non-engaged Veterans, but for certain specific services (eg, VHA homeless services), there may be differences in proportion with rural residence. (Moderate strength evidence)
- We found insufficient evidence on the effects of rurality on differences in health services utilization, health behaviors, or health outcomes between engaged and non-engaged Veterans.
- Trauma exposure is higher for Veterans engaged versus not engaged in VHA care. (Low strength of evidence)
- No articles addressed the role of trauma exposure in differences in health services access, health behaviors, or health outcomes between engaged and non-engaged Veterans.
- No included articles investigated sexual orientation or gender identity among engaged and non-engaged Veterans.

### Evidence Map

Forty included articles examined social determinants of interest for Veterans engaged and not engaged in VHA services and/or benefits. Most articles used cross-sectional data and education, marital status, income, and employment were the most frequently included determinants (Appendix C, Table 3). Fewer articles examined the role of social determinants in health behaviors, health services access or utilization, and/or health outcomes (Figure 6 and Appendix C, Table 3). Several of the social determinants were examined in less than 10 articles, including trauma exposure and social support.

Figure 6 Summary of Included Articles Addressing Social Determinants and Various Outcomes for Veterans Engaged and Not Engaged in VHA Care^a^ a Shading in a cell represents the number of articles; rows are social determinants of interest and columns are for total number of eligible articles followed by number of eligible article reporting a health-related outcome of interest

### Qualitative Synthesis of Results for Rurality, Trauma, Sexual Orientation and Gender Identity for Veterans Engaged and Not Engaged in VHA Care

We found 14 articles which examined rurality, 6 which addressed trauma, and none for sexual orientation or gender identity (Table 3). Most articles on rurality and/or trauma used nationally representative datasets. While most articles on rurality included more than 5000 participants and included both men and women, most articles on trauma had 1000 or fewer participants and 4 included only women. Two articles investigated the role of rurality on health services access or utilization, and/or various health outcomes; no rurality articles examined health behaviors. No articles addressed the role of trauma exposure in health services utilization, health behaviors, or health outcomes of interest. Detailed results from included articles on rurality and trauma are provided in Appendix C, Table 4 and described below.

Table 3 Characteristics of Included Articles for Rurality and Trauma—Veterans Engaged and Not Engaged in VHA Services or Benefits

| Rurality^a^* | Trauma
Total number of articles | 14 | 6
Nationally representative dataset | 12 | 4
Exclusively men | 2 | —
Exclusively women | — | 4
Number of participants: | | 2
100-1000 | 2 | 4
1001-5000 | 2 | 2
>5000 | 9 | —
Quality:
Low | 4 | 4
Medium | 8 | 2
High | 2 | —
Examined role of social determinant in:
Health behaviors | — | —
Health services access or utilization | 2 | —
Mental health | — | —
General health | 1 | —
Mortality | — | —
Other health outcomes | 1 | —

a Number of participants unclear in one study (Ajmera 2011^14^); articles may be included in more than one category

#### Rurality

Articles on rurality for engaged and non-engaged Veterans were mostly of medium or low quality, with only 2 being high quality. As in articles examining rurality for Veterans and non-Veterans, these articles used a variety of measures of rurality (eg, MSA,^14,48,130^ self-reported rural/urban residence,^63,100,113^ and RUC codes,^74,129^ Appendix C, Table 4). Additionally, several articles used Rural-Urban Commuting Area (RUCA) codes^19,40,41^ and one assessed straight-line distances between participant homes and the nearest VHA facility.^91^ Articles used datasets across 3 decades (1997-2013) and a variety of sources, including large nationally representative surveys, VHA administrative data, and local surveys. In general, articles found small or no difference in the proportion of rural residence between engaged and non-engaged Veterans, with prevalence estimates ranging from 6-26%. For example, one article using 2000 BRFSS data reported 30% of engaged Veterans and 24% of non-Veterans resided in “non-metropolitan” areas (defined by RUC codes).^129^ One article found differences in rural residence (engaged Veterans 18% rural vs non-engaged 28%), but focused exclusively on Native Americans who were enrolled in VHA and the Indian Health Service, and also included non-Veterans in the non-engaged group.^74^ Two articles which were rated high quality both used VHA data, and one used VHA classification of rural vs urban,^66^ and the other employed zipcode-based approximations of RUCA.^19^ Hynes et al^66^ compared Veterans who utilized VHA services with those who used services paid by Medicare, finding little difference in rural residence (21% vs 19 %). Blackstock et al^19^ compared Veterans who used or did not use VHA homeless service, and reported 15% rural residence among those who accessed these services compared with 21% for Veterans who did not.

Only 3 articles investigated the role of rurality in health services access or utilization and/or health outcomes, and all were of medium quality.^14,129,130^ No articles examined the role of rurality in health behaviors (Appendix C Table 4). One article reported no substantial difference between metropolitan and non-metropolitan participants in proportion having a “checkup” within prior 2 years,^129^ and the other article found significant interaction effects between rural residence and a combined Veteran/VHA user categorical variable (ie, non-Veteran, Veteran VHA user, and Veteran non-VHA user) in associations with total healthcare expenditures but did not report the magnitude of the interaction effect.^130^ Both articles examining the role of rurality in health outcomes^14,129^ found no significant effects for rurality; one looked at days of poor physical or mental health or otherwise limited by health,^129^ and the other determined associations with hospitalization for ambulatory-care sensitive conditions (Appendix C, Table 4).^14^

#### Trauma

None of the 6 articles examining trauma exposures for engaged and non-engaged Veterans were rated as being high quality; 3 articles^100,108,113^ were rated as being medium quality. Across all articles, engagement with VHA was based on self-report of whether individuals were current or recent users of VHA services vs past or never users. As with articles comparing Veterans and non-Veterans, a variety of trauma types and measures were studied, with little consistency across studies. One article examined adverse childhood experiences and adult experience of sexual trauma or IPV,^81^ 3 articles addressed combat-related trauma and sexual or non-combat related physical trauma specific to military service,^81,100,108^ one article examined history of military sexual assault,^52^ and one article examined Vietnam war-zone service.^52^ One article investigated military trauma related to sexual minority status.^113^

Estimates of trauma prevalence were primarily unadjusted and somewhat consistent across articles comparing engaged and non-engaged Veterans, with 5 finding higher prevalence among engaged,^45,52,81,108,113^ and one finding no difference in prevalence between engaged and non-engaged.^100^ One article addressed combat trauma, reporting higher prevalence among engaged in unadjusted estimates, but no significant differences in adjusted estimates.^108^ Another article examined prevalence of military trauma related to sexual orientation, finding no difference in unadjusted estimates, but positive associations with VHA use in adjusted analyses.^113^