# REFERENCES

1 Institute of Medicine. Capturing social and behavioral domains and measures in electronic health records: Phase 2. Washington DC: The National Academies Press; 2014.
2 Tarlov AR. Public policy frameworks for improving population health. Ann NY Acad Sci. 1999;896(1):281-293.10681904
3 Phelan JC, Link BG, Tehranifar P. Social conditions as fundamental causes of health inequalities: theory, evidence, and policy implications. J Health Soc Behav. 2010;51(1 Suppl):S28-S40.20943581
4 Marmot MG, Shipley MJ, Rose G. Inequalities in death—specific explanations of a general pattern? Lancet. 1984;323(8384):1003-1006.
5 Marmot MG, Stansfeld S, Patel C, . Health inequalities among British civil servants: the Whitehall II study. Lancet. 1991;337(8754):1387-1393.1674771
6 Adler NE, Stewart J. Health disparities across the lifespan: meaning, methods, and mechanisms. Ann NY Acad Sci. 2010;1186:5-23.20201865
7 Bragge P, Clavisi O, Turner T, Tavender E, Collie A, Gruen RL. The Global Evidence Mapping Initiative: scoping research in broad topic areas. BMC Med Res Methodol. 2010;11:92.
8 Ryan RE, Kaufman CA, Hill SJ. Building blocks for meta-synthesis: data integration tables for summarising, mapping, and synthesising evidence on interventions for communicating with health consumers. BMC Med Res Methodol. 2009;9:16.19261177
9 MacArthur Foundation. Research Network on Socioeconomic Status & Health. Available at: https://www.macfound.org/networks/research-network-on-socioeconomic-status-health/, Accessed 20 September 2017.
10 Kondo K, Low A, Everson T, . Prevalence of and Interventions to Reduce Health Disparities in Vlunerable Veteran Populations: A Map of the Evidence. VA Evidence-based Synthesis Program Report, 2017. Available at https://www.hsrd.research.va.gov/publications/esp/DisparitiesInterventions.pdf, Accessed 20 September 2017.
11 Teachman J. Are veterans healthier? Military service and health at age 40 in the all-volunteer era. Soc Sci Res. 2011;40:326-335.
12 Owens DK, Lohr KN, Atkins D, . AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-523.19595577
13 Abraham KM, Ganoczy D, Yosef M, Resnick SG, Zivin K. Receipt of employment services among Veterans Health Administration users with psychiatric diagnoses. J Rehabil R D. 2014;51(3):401-414.
14 Ajmera M, Wilkins TL, Sambamoorthi U. Dual Medicare and Veteran Health Administration use and ambulatory care sensitive hospitalizations. J Gen Intern Med. 2011;26(Suppl 2):669-675.
15 Baldwin CM, Long K, Kroesen K, Brooks AJ, Bell IR. A profile of military Veterans in the southwestern United States who use complementary and alternative medicine. Arch Intern Med. 2002;162(15):1697-1704.12153372
16 Bareis N, Mezuk B. The relationship between childhood poverty, military service, and later life depression among men: evidence from the Health and Retirement Study. J Affect Disord. 2016;206:1-7.27455351
17 Barrera TL, Cully JA., Amspoker AB, .. Cognitive–behavioral therapy for late-life anxiety: Similarities and differences between Veteran and community participants. J Anxiety Disord. 2015;33:72-80.26005839
18 Bastian LA, Gray KE, DeRycke E, . Differences in active and passive smoking exposures and lung cancer incidence between Veterans and non-Veterans in the Women's Health Initiative. Gerontologist. 2016;56:S102-S111.26768384
19 Blackstock OJ, Haskell SG., Brandt CA, Desai RA. Gender and the use of veterans health administration homeless services programs among Iraq/Afghanistan veterans. Med Care. 2012;50(4):347-352.22422055
20 Blosnich J, Foynes MM, Shipherd JC. Health disparities among sexual minority women veterans. J Womens Health. 2013;22(7):631-636.
21 Blosnich J, Bossarte R, Silver E, Silenzio V. Health care utilization and health indicators among a national sample of US veterans in same-sex partnerships. Mil Med. 2013;178(2):207-212.23495467
22 Blosnich JR, Dichter ME, Cerulli C, Batten SV, Bossarte RM. Disparities in adverse childhood experiences among individuals with a history of military service. JAMA Psychiatry. 2014;71(9):1041-1048.25054690
23 Bohnert ASB, Ilgen MA, Bossarte RM, Britton PC, Chermack ST, Blow FC. Veteran status and alcohol use in men in the United States. Mil Med. 2012;177(2):98-203.
24 Bookwala J, Frieze IH, Grote N. The long-term effects of military service on quality of life: The Vietnam experience. J Appl Soc Psychol. 1994;24(6):529-545.
25 Boscarino JA, Sitarik A, Gordon SC, . Risk factors for hepatitis C infection among Vietnam era veterans versus nonveterans: results from the Chronic Hepatitis Cohort Study (CHeCS). J Community Health. 2014;39(5):914-921.24682941
26 Brown C, Routon PW. Military service and the civilian labor force: time- and income-based evidence. Armed Forces Soc. 2016;42(3):562-584.
27 Cerulli C, Bossarte RM, Dichter ME. Exploring intimate partner violence status among male veterans and associated health outcomes. Am J Mens Health. 2014;8(1):66-73.23832953
28 Chi RC, Reiber GE, Neuzil KM. Influenza and pneumococcal vaccination in older veterans: results from the behavioral risk factor surveillance system. J Am Geriatr Soc. 2006;54(2):217-223.16460371
29 Cordray SM, Polk KR, Britton BM. Premilitary antecedents of post-traumatic stress disorder in an Oregon cohort. J Clin Psychol. 1992;48(3):271-280.1602015
30 Cowper DC, Longino CF, Kubal JD, Manheim LM, Dienstfrey SJ, Palmer JM. The retirement migration of US Veterans, 1960, 1970, 1980, and 1990. J Appl Gerontol. 2000;19:123-137.
31 Culp R, Youstin TJ, Englander K, Lynch J. From war to prison: examining the relationship between military service and criminal activity. Justice Q. 2013;30(4):651-680.
32 Currier JM, McDermott RC, Sims BM. Patterns of help-seeking in a national sample of student veterans: A matched control group investigation. Gen Hosp Psychiatry. 2016;43:58-62.27796259
33 De Luca SM, Blosnich JR, Hentschel EAW, King E, Amen S. Mental health care utilization: how race, ethnicity and veteran status are associated with seeking help. Community Ment Health J. 2016;52(2):174-179.26659853
34 Dichter ME, Cerulli C, Bossarte RM. Intimate partner violence victimization among women veterans and associated heart health risks. Womens Health Issues. 2011;21(4 Suppl):S190-S194..21724140
35 Dunne EM, Burrell LE, Diggins AD, Whitehead NE, Latimer WW. Increased risk for substance use and health-related problems among homeless veterans. Am J Addict. 2015;24(7):676-680.26359444
36 Dursa EK, Bart SK, Bossarte RM, Schneiderman AI. Demographic, military, and health characteristics of VA health care users and nonusers who served in or during Operation Enduring Freedom or Operation Iraqi Freedom, 2009-2011. Public Health Rep. 2016;131(6):839-843.28123232
37 Elder GH, Shanahan MJ, Clipp EC. When war comes to men's lives: life-course patterns in family, work, and health. Psychol Aging. 1994;9(1):5-16.8185868
38 Elhai JD, Frueh BC, Gold PB, Gold SN, Hamner MB. Clinical presentations of posttraumatic stress disorder across trauma populations: A comparison of MMPI-2 profiles of combat veterans and adult survivors of child sexual abuse. J Nerv Ment Dis. 2000;188(10):708-713.11048821
39 Faestel PM, Littell CT, Vitiello MV, Forsberg CW, Littman AJ. Perceived insufficient rest or sleep among veterans: Behavioral Risk Factor Surveillance System 2009. J Clin Sleep Med. 2013;9(6):577-584.23772191
40 French DD, Margo CE. Factors associated with the utilization of cataract surgery for veterans dually enrolled in Medicare. Mil Med. 2012;177(6):752-756.22730855
41 French DD, Bradham DD, Campbell RR, . Factors associated with program utilization of radiation therapy treatment for VHA and medicare dually enrolled patients. J Community Health. 2012;37(4):882-887.22139021
42 Fulton LV, Belote JM, Brooks MS, Coppola MN. A comparison of disabled veteran and nonveteran income: time to revise the law? J Disabil Policy Stud. 2009;20(3):184-191.
43 Gabrielian S, Yuan AH, Andersen RM, Rubenstein LV, Gelberg L. VA health service utilization for homeless and low-income veterans: a spotlight on the VA Supportive Housing (VASH) program in greater Los Angeles. Med Care. 2014;52(5):454-461.24714583
44 Gabrielian S, Burns AV, Nanda N, Hellemann G, Kane V, Young AS. Factors associated with premature exits from supported housing. Psychiatr Serv. 2016;67(1):86-93.26467908
45 Gamache G, Rosenheck RA, Tessler R. Factors predicting choice of provider among homeless veterans with mental illness. Psychiatr Serv. 2000;51(8):1024-1028.10913456
46 Gamache G, Rosenheck R, Tessler R. The proportion of veterans among homeless men: a decade later. Soc Psychiatry Psychiatr Epidemiol. 2001;36(10):481-485.11768845
47 Gfeller JD, Roskos PT. A comparison of insufficient effort rates, neuropsychological functioning, and neuropsychiatric symptom reporting in military veterans and civilians with chronic traumatic brain injury. Behav Sci Law. 2013;31(6):833-849.24123226
48 Gorman LA, Sripada RK, Ganoczy D, . Determinants of National Guard mental health service utilization in VA versus non-VA settings. Health Serv Res. 2016;51(5):1814-1837.26840993
49 Gould CE, Rideaux T, Spira AP, Beaudreau SA. Depression and anxiety symptoms in male veterans and non?veterans: The Health and Retirement study. Int J Geriatr Psychiatry. 2015;30(6):623-630.25145943
50 Greenberg GA, Rosenheck RA, Desai RA. Risk of Incarceration among male veterans and nonveterans: are veterans of the all volunteer force at greater risk? Armed Forces Soc. 2007;33(3):337-350.
51 Grossbard JR, Lehavot K, Hoerster KD, Jakupcak M, Seal KH, Simpson TL. Relationships among veteran status, gender, and key health indicators in a national young adult sample. Psychiatr Serv. 2013;64(6):547-553.23450338
52 Hamilton AB, Frayne SM, Cordasco KM, Washington DL. Factors related to attrition from VA healthcare use: findings from the National Survey of Women Veterans. J Gen Intern Med. 2013;28(Suppl 2):510-516.
53 Hammett P, Fu SS, Lando HA, Owen G, Okuyemi KS. The association of military discharge variables with smoking status among homeless Veterans. Prev Med. 2015;81:275-280.26400636
54 Hardy MA, Reyes AM. The longevity legacy of World War II: the intersection of GI status and mortality. Gerontologist. 2016;56(1):104-114.26220413
55 Hartley TA, Violanti JM, Mnatsakanova A, Andrew ME, Burchfiel CM. Military experience and levels of stress and coping in police officers. Int J Emerg Ment Health. 2013;15(4):229-239.24707586
56 Hedrick B, Pape TL, Heinemann AW, Ruddell JL, Reis J. Employment issues and assistive technology use for persons with spinal cord injury. J Rehabil R D. 2006;43(2):185-198.
57 Henderson C, Bainbridge J, Keaton K, Kenton M, Guz M, Kanis B. The use of data to assist in the design of a new service system for homeless veterans in New York City. Psychiatr Q. 2008;79(1):3-17.18060499
58 Heslin KC, Guerrero EG, Mitchell MN, Afable MK, Dobalian A. Explaining differences in hepatitis C between US veterans and nonveterans in treatment for substance abuse: results from a regression decomposition. Subst Use Misuse. 2013;48(10):854-862.23869458
59 Hisnanick JJ. Changes over time in the ADL status of elderly US veterans. Age Ageing. 1994;23(6):505-511.9231946
60 Hoerster KD, Lehavot K, Simpson T, McFall M, Reiber G, Nelson KM. Health and health behavior differences: US Military, veteran, and civilian men. Am J Prev Med. 2012;43(5):483-489.23079170
61 Hoff RA, Rosenheck RA. The use of VA and non-VA mental health services by female veterans. Med Care. 1998;36(11):1524-1533.9821940
62 Hoglund MW, Schwartz RM. Mental health in deployed and nondeployed veteran men and women in Comparison with their civilian counterparts. Mil Med. 2014;179(1):19-25.
63 Houston TK, Volkman JE, Feng H, Nazi KM, Shimada SL, Fox S. Veteran Internet use and engagement with health information online. Mil Med. 2013;178(4):394-400.23707823
64 Howren MB, Cai X, Rosenthal G, Vander Weg MW. Associations of health-related quality of life with healthcare utilization status in veterans. Appl Res Qual Life. 2012;7(1):83-92.
65 Hoy-Ellis CP, Shiu C, Sullivan KM, Kim H-J, Sturges AM, Fredriksen-Goldsen KI. Prior military service, identity stigma, and mental health among transgender older adults. Gerontologist. 2017;57(Suppl 1):S63-S71.28087796
66 Hynes DM, Koelling K, Stroupe K, . Veterans' access to and use of Medicare and Veterans Affairs health care. Med Care. 2007;45(3):214-223.17304078
67 Johnson AM, Rose KM, Elder GH, Chambless LE, Kaufman JS, Heiss G. Military combat and burden of subclinical atherosclerosis in middle aged men: the ARIC study. Prev Med. 2010;50:277-281.20184920
68 Johnson AM, Rose KM, Elder GH, Chambless LE, Kaufman JS, Heiss G. Military combat and risk of coronary heart disease and ischemic stroke in aging men: The Atherosclerosis Risk in Communities (ARIC) study. Ann Epidemiol. 2010;20(2):143-150.20123165
69 Kaplan MS, Huguet N, McFarland BH, Newsom JT. Suicide among male veterans: a prospective population-based study. J Epidemiol Community Health. 2007;61(7):619-624.17568055
70 Katon JG, Lehavot K, Simpson T, . Adverse childhood experiences, military service, and adult health. Am J Prev Med 2015;49(4):573-582.26091925
71 Kleykamp M. Unemployment, earnings and enrollment among post 9/11 veterans. Soc Sci Res. 2013;42(3):836-851.23521998
72 Koepsell T, Reiber G, Simmons KW. Behavioral risk factors and use of preventive services among veterans in Washington State. Prev Med. 2002;35(6):557-562..12460523
73 Koepsell TD, Littman AJ, Forsberg CW. Obesity, overweight, and their life course trajectories in veterans and non-veterans. Obesity. 2012;20(2):434-439.21293452
74 Kramer BJ, Wang M, Jouldjian S, Lee ML, Finke B, Saliba D. Veterans Health Administration and Indian Health Service: healthcare utilization by Indian Health Service enrollees. Med Care. 2009;47(6):670-676.19433994
75 Kramer BJ, Jouldjian S, Wang M .. Do correlates of dual use by American Indian and Alaska Native veterans operate uniformly across the Veterans Health Administration and the Indian Health Service? J Gen Intern Med. 2011;26(Suppl 2):662-668.21989619
76 LaCroix AZ, Rillamas-Sun E, Woods NF, . Aging well among women Veterans compared with non-Veterans in the Women's Health Initiative. Gerontologist. 2016;56(Suppl 1):S14-S26.26768388
77 Laudet A, Timko C, Hill T. Comparing life experiences in active addiction and recovery between veterans and non-veterans: a national study. J Addict Dis. 2014;33(2):148-162.24783976
78 LaVela SL, Prohaska TR, Furner S, Weaver FM. Preventive healthcare use among males with multiple sclerosis. Public Health. 2012;126(10):896-903.22795651
79 Lehavot K, Hoerster KD, Nelson KM, Jakupcak M, Simpson TL. Health indicators for military, veteran, and civilian women. Am J Prev Med. 2012;42(5):473-480.22516487
80 Lehavot K, Katon JG, Williams EC, . Sexual behaviors and sexually transmitted infections in a nationally representative sample of women veterans and nonveterans. J Womens Health. 2014;23(3):246-252.
81 Lehavot K, O'Hara R, Washington DL, Yano EM, Simpson TL. Posttraumatic stress disorder symptom severity and socioeconomic factors associated with Veterans Health Administration use among women veterans. Womens Health Issues. 2015;25(5):535-541.26123641
82 Lehavot K, Rillamas-Sun E, Weitlauf J, . Mortality in postmenopausal women by sexual orientation and veteran status. Gerontologist. 2016;56(Suppl 1):S150-S162.26768389
83 Little RD, Fredland JE. Veteran status, earnings, and race: some long term results. Armed Forces Soc. 1979;5(2):244-260.
84 London AS, Heflin CM, Wilmoth JM. Work-related disability, veteran status, and poverty:implications for family well-being. J Poverty. 2011;15(3):330-349.
85 Long JA, Polsky D, Asch DA. Receipt of health services by low-income veterans. J Health Care Poor Underserved. 2003;14(3):305-317.12955911
86 Lopreato SC, Poston DL. Differences in earnings and earnings ability between black veterans and nonveterans in the United States. Soc Sci Q. 1977;57(4):750-766.
87 MacLean A. Lessons from the cold war: military service and college education. Sociol Educ. 2005;78(3):250-266.
88 MacLean A, Kleykamp M. Income inequality and the veteran experience. Ann Am Acad Pol Soc Sci. 2016;663:99-116.
89 Marrie RA, Cutter G, Tyry T, Campagnolo D, Vollmer T. Differences in bladder care for veterans with multiple sclerosis by treatment location. Int J MS Care. 2009;11(2):91-97.
90 Martindale M, Poston DL. Variations in veteran/nonveteran earnings patterns among World War II, Korea, and Vietnam War cohorts. Armed Forces Soc. 1979;5(2):219-243.
91 McCarthy JF, Valenstein M, Dixon L, Visnic S, Blow FC, Slade E. Initiation of assertive community treatment among veterans with serious mental illness: client and program factors. Psychiatr Serv. 2009;60(2):196-201.19176413
92 McCaskill GM, Sawyer P, Burgio KL, . The impact of veteran status on life-space mobility among older black and white men in the deep south. Ethn Dis. 2015;25(3):255-262.26675739
93 McCauley HL, Blosnich JR, Dichter ME. Adverse childhood experiences and adult health outcomes among veteran and non-veteran women. J Womens Health. 2015;24(9):723-729.
94 McLay RN, Lyketsos CG. Veterans have less age-related cognitive decline. Mil Med. 2000;165(8):622-625.10957857
95 Murdoch M, Sayer NA, Spoont M, . Long-term outcomes of disability benefits in US veterans with posttraumatic stress disorder. Arch Gen Psychiatry. 2011;68(10):1072-1080.21969464
96 Naifeh JA, North TC, Davis JL, Reyes G, Logan CA, Elhai JD. Clinical profile differences between PTSD-diagnosed military veterans and crime victims. J Trauma Dissociation. 2008;9(3):321-334.19042781
97 Nelson KM. The burden of obesity among a national probability aample of veterans. J Gen Intern Med. 2006;21(9):915-919.16918734
98 Nyamathi A, Sands H, Pattatucci-Aragón A, . Perception of health status by homeless US veterans. Fam Community Health. 2004;27(1):65-74.14724503
99 O'Donnell JC. Military service and mental health in later life. Mil Med. 2000;165(3):219-223.10741087
100 Ouimette P, Wolfe J, Daley J, G K. Use of VA health care services by women veterans: findings from a national sample. Women Health. 2003;38(2):77-91.
101 Padula CB, Weitlauf JC, Rosen AC, . Longitudinal cognitive trajectories of women veterans from the Women's Health Initiative Memory Study. Gerontologist. 2016;56(1):115-125.26615021
102 Petrovich JC, Pollio DE, North CS. Characteristics and service use of homeless veterans and nonveterans residing in a low-demand emergency shelter. Psychiatr Serv. 2014;65(6):751-757.24535542
103 Phillips BR, Shahoumian TA, Backus LI. Surveyed enrollees in veterans affairs health care: How they differ from eligible veterans surveyed by BRFSS. Mil Med. 2015;180(11):1161-1169.26540708
104 Prokos A, Padavic I. Earn all that you can earn: income differences between women veterans and non-veterans. J Polit Mil Soc. 2000;28(1):60-74.
105 Randall M, Kilpatrick KE, Pendergast JF, Jones KR, Vogel B. Differences in patient characteristics between Veterans Administration and community hospitals. Med Care. 1987;25(11):1099-1104.3695640
106 Rosenheck R, Koegel P. Characteristics of veterans and nonveterans in three samples of homeless men. Hosp Community Psychiatry. 1993;44:(9):858-863.8225299
107 Rosenheck R, Frisman L, Chung A-M. The proportion of veterans among homeless men. Am J Public Health. 1994;84(3):466-469.8129068
108 Ryan ET, McGrath A, Creech SK, Borsari B. Predicting utilization of healthcare services in the Veterans Health Administration by returning women veterans: the role of trauma exposure and symptoms of posttraumatic stress. Psychol Serv. 2015;12(4):412-419.26524283
109 Saban KL, Bryant FB, Reda DJ, Stroupe KT, Hynes DM. Measurement invariance of the kidney disease and quality of life instrument (KDQOL-SF) across veterans and non-veterans. Health Qual Life Outcomes. 2010;8:120.20973987
110 Sayer NA, Orazem RJ, Noorbaloochi S, . Iraq and Afghanistan War veterans with reintegration problems: differences by Veterans Affairs healthcare user status. Adm Policy Ment Health. 2015;42(4):493-503.24913102
111 Schultz JR, Bell KM, Naugle AE, Polusny MA. Child sexual abuse and adulthood Sexual assault among military veteran and civilian women. Mil Med. 2006;171(8):723-728.16933812
112 Shen C, Sambamoorthi U. Associations between health-related quality of life and financial barriers to care among women veterans and women non-veterans. Women Health. 2012;52(1):1-17.22324355
113 Simpson TL, Balsam KF, Cochran BN, Lehavot K, Gold SD. Veterans administration health care utilization among sexual minority veterans. Psychol Serv. 2013;10(2):223-232.23730965
114 Smith I, Marsh K, Segal DR. The World War II veteran advantage? a lifetime cross-sectional study of social status attainment. Armed Forces Soc. 2012;38(1):5-26.
115 Smith RW, Young HH. Symptom patterns of psychiatrically diagnosed veterans who request treatment and those who do not. Psychol Rep. 1968;22(3):1001-1005.5653347
116 Sparks PJ, Bollinger M. A demographic profile of obesity in the adult and veteran US populations in 2008. Popul Res Policy Rev. 2011;30(3):211-233.
117 Teachman J. Military service in the Vietnam era and educational attainment. Sociol Educ 2005;78(1):60-68.
118 Teachman JD, Call VRA. The effect of military service on educational, occupational, and income attainment. Soc Sci Res. 1996;25(1):1-31.
119 Tessler R, Rosenheck R, Gamache G. Comparison of homeless veterans with other homeless men in a large clinical outreach program. Psychiatr Q. 2002;73(2):109-119.12025719
120 Tessler R, Rosenheck R, Gamache G. Homeless veterans of the all-volunteer force: a social selection perspective. Armed Forces Soc. 2003;29(4):509-524.
121 Tran TV, Canfield J, Chan K. The association between unemployment status and physical health among veterans and civilians in the United States. Soc Work Health Care. 2016;55(9):720-731.27348549
122 Tsai J, Mares AS, Rosenheck RA. Do homeless veterans have the same needs and outcomes as non-veterans? Mil Med. 2012;177(1):27-31.22338975
123 Tsai J, Mota NP, Pietrzak RH. US Female veterans who do and do not rely on VA health care: needs and barriers to mental health treatment. Psychiatr Serv. 2015;66(11):1200-1206.26174948
124 Vinokur A, Caplan RD, Williams CC. Effects of recent and past stress on mental health: coping with unemployment among Vietnam veterans and nonveterans. J Appl Soc Psychol. 1987;17(8):710-730.
125 Vollmer TL, Hadjimichael O, Preiningerova J, Ni W, Buenconsejo J. Disability and treatment patterns of multiple sclerosis patients in United States: a comparison of veterans and nonveterans. J Rehabil R D. 2002;39(2):163-174.
126 Washington DL, Yano EM, Simon B, Sun S. To use or not to use. what influences why women veterans choose VA health care. J Gen Intern Med. 2006;21(Suppl 3):S11-S18.16637939
127 Washington DL, Gray K, Hoerster KD, . Trajectories in physical activity and sedentary time among women veterans in the Women's Health Initiative. Gerontologist. 2016;56(Suppl 1):S27-S39.26768390
128 Washington DL, Bird CE, LaMonte MJ, . Military generation and its relationship to Mortality in women veterans in the Women's Health Initiative. Gerontologist. 2016;56(Suppl 1):S126-S137.26768386
129 West A, Weeks WB. Physical and mental health and access to care among nonmetropolitan Veterans Health Administration patients younger than 65 years. J Rural Health. 2006;22(1):9-16.16441331
130 West AN, Weeks WB. Health care expenditures for urban and rural veterans in Veterans Health Administration care. Health Serv Res. 2009;44(5 Pt 1):1718-1734.19500162
131 White MD, Mulvey P, Fox AM, Choate D. A hero's welcome? Exploring the prevalence and problems of military veterans in the arrestee population. Justice Q. 2012;29(2):258-286.
132 White R, Barber C, Azrael D, Mukamal KJ, Miller M. History of military service and the risk of suicidal ideation: findings from the 2008 National Survey on Drug Use and Health. Suicide LifeThreat Behav. 2011;41(5):554-561.
133 Whiteman SD, Barry AE, Mroczek DK, Macdermid Wadsworth S. The development and implications of peer emotional support for student service members/veterans and civilian college students. J Couns Psychol. 2013;60(2):265-278.23421774
134 Widome R, Laska MN, Gulden A, Fu SS, Lust K. Health risk behaviors of Afghanistan and Iraq war veterans attending college. Am J Health Promot. 2011;26(2):101-108.22040391
135 Williams BA, McGuire J, Lindsay RG, . Coming home: health status and homelessness risk of older pre-release prisoners. J Gen Intern Med. 2010;25(10):1038-1044.20532651
136 Wilmoth JM, London AS, Heflin CM. Economic well-being among older-adult households: variation by veteran and disability status. J Gerontol Soc Work. 2015;58(4):399-419.25750998
137 Winkleby MA, Fleshin D. Physical, addictive, and psychiatric disorders among homeless veterans and nonveterans. Public Health Rep. 1993;108(1):30-36.8434094
138 Wittrock S, Ono S, Stewart K, Reisinger HS, Charlton M. Unclaimed health care benefits: a mixed-method analysis of rural veterans. J Rural Health. 2015;31(1):35-46.25052886
139 Wong ES, Wang V, Liu C-F, Hebert PL, Maciejewski ML. Do Veterans Health Administration enrollees generalize to other populations? Med Care Res Rev. 2016;73(4):493-507.26589675
140 Zemencuk JK, Hayward RA, Skarupski KA, Katz SJ. Patients' desires and expectations for medical care: a challenge to improving patient satisfaction. Am J Med Qual. 1999;14(1):21-27.10446660
141 Smith DL. The relationship of disability and employment for veterans from the 2010 Medical Expenditure Panel Survey (MEPS). Work. 2015;51(2):349-363.25425598
142 Bernard DM, Selden TM. Access to care among nonelderly Veterans. Med Care. 2016;54(3):243-252.26871642
143 Department of Veterans Affairs. Blueprint for Excellence: Veterans Health Administration. Available at: https://www.va.gov/health/docs/vha_blueprint_for_excellence.pdf, Accessed 20 September 2017.
144 Berke EM, West AN, Wallace AE, Weeks WB. Practical and policy implications of using different rural-urban classification systems: A case study of inpatient service utilization among Veterans Administration users. J Rural Health. 2009;25(3):259-266.19566611
145 Hartley D. Rural health disparities, population health, and rural culture. Am J Public Health. 2004;94(10):1675-1678.15451729
146 Wang L, Elder GH, Spence NJ. Status configurations, military service and higher education. Soc Forces. 2012;91(2):397-422.24511161