# METHODS

## DEVELOPMENT OF CONCEPTUAL AND ANALYTIC FRAMEWORKS

In developing our approach for systematically identifying, describing, and interpreting the evidence base for social determinants of Veterans' health, we worked with our VHA partners to first establish a conceptual framework that depicts the complex relationships between social determinants of health, Veteran status or experiences, and health outcomes (Figure 1). This framework draws upon work from the MacArthur Research Network on Socioeconomic Status and Health^9^ and the IOM report on prioritization of social determinants for capture by health records.^1^ We sought to be inclusive and broad in conceptualizing relevant social determinants, but also considered whether particular social determinants have available measures, and whether they are considered as high priority by national groups and our VHA partners (Table 1). We note that while certain social determinants are consistently named but variably defined or measured (eg, income), other social determinants are both inconsistently described and measured (eg, exposures to trauma and adversity), thus limiting our ability to compare across past reports and existing frameworks. Nevertheless, development of this conceptual framework with our VHA partners and identification of a starting set of social determinants were critical for clarifying the objectives of our partners and informing our search strategies.

Figure 1 Conceptual Framework for Social Determinants of Veterans' Health

a Veteran Status/Experience refers to whether one is a Veteran, including deployed and non-deployed, and various eras of service

Table 1 Social Determinants of Health

| Standardized Measure Available | High Priority^a^ for Capture by Health Records
Individual Factors:
Education | ✓ | ✓
Employment | ✓ | ✓
Income | ✓ | NR
Sexual Orientation | | ✓
Gender Identity | | NR
Social Relationships and Living Conditions:
Marital Status | ✓ | NR
Social Support | ✓ | ✓
Family SES | | ✓
Trauma History | ✓ | ✓
Justice Involved | | NR
Housing Status | | NR
Rurality | ✓ | NR

a Results adapted from report by Institute of Medicine (2014) Capturing social and behavioral domains and measures in electronic health records: Phase 2; NR = not rated in report

Our conceptual framework highlights some of the complexities arising in the study of social determinants. First, we separated age, race/ethnicity, and sex into their own category, as key demographic characteristics that are distinct from social determinants of health. We acknowledge that these factors have social components (eg, definitions of race and ethnicity) and likely interact with social determinants, but they also may be associated with biologic/physiologic variation that impacts health through non-social pathways. The different pathways by which age, race, and sex impact health are often not distinguished in studies examining outcomes, and attempting to understand the “social” components is beyond the scope of this evidence review. Furthermore, a recent VHA ESP report has focused on health disparities among Veterans, and thus, evaluated the current evidence base for health outcomes associated with these key demographic factors.^10^ Thus, our expectation is that robust analyses of impact of social determinants should account for age, race, and sex, in alignment with our main goal of examining the evidence base for social determinants against the backdrop of known impacts of these factors.

Other important considerations include the potential for differential selection of individuals into military service along one or more dimensions of social determinant, nonlinearity in relationships between factors, feedback loops within the complex system of relationships, and interactive dynamic effects due to bidirectionality. Over the life course, pathways are also likely to vary in their influence on health outcomes (eg, adversity in childhood vs adulthood). Our model also depicts how social determinants may influence Veteran experiences and engagement with VHA resources, with Veteran status being a mediator of social determinants on health outcomes. For example, a study examining the role of social determinants in health of Veterans compared with non-Veterans addressed the need to distinguish between potential impact of social determinants on differential selection into military service and the other pathways by which social determinants may impact health for Veterans.^11^ Alternatively, Veteran status or experience may impact social determinants (eg, effect on educational attainment or access to affordable housing), in which case social determinants are mediating the health effects of Veteran status. Additionally, social determinants could moderate the relationship between Veteran experiences and health (ie, differentially modulating the strength or direction of such associations). Importantly, these distinct roles of social determinants would be examined using different analytic techniques (eg, tests for mediation vs examining interaction effects). For example, if trauma exposures have moderating effects, we might observe that the association between Veteran status and health outcome is stronger or weaker among Veterans who have experienced trauma, compared with non-Veterans who have similar exposures. In contrast, if trauma mediates the impact of Veteran status on health, we would find that accounting for trauma exposure would decrease or change the associations between Veteran experiences and health outcomes.

In accordance with our conceptual framework, we developed 2 analytic frameworks (Figures 2 and 3) to further clarify our key questions and inform our search strategies. The analytic frameworks helped to identify the populations of interest, highlight social determinants that are likely relevant, define outcomes of interest, and determine the inclusion/exclusion criteria for the evidence review. In comparing our analytic frameworks with the more complex conceptual framework described above, we note 2 key simplifications. First, we are primarily concerned with social determinants as mediators of the effects of Veteran status, or engagement in VHA services or benefits. Thus, in the analytic frameworks, we have not included the potential impact of social determinants on Veteran status (Figure 2) or engagement with the VHA among Veterans (Figure 3). Second, we have indicated unidirectional relationships throughout (eg, social determinants affecting health directly, or affecting health services access which in turn affects health) because these are the associations most likely to be examined by published studies, and they are most relevant to addressing the policy concerns of our VHA partners. Evaluating bidirectional relationships between social determinants and health would require robust longitudinal data and more complex analytic techniques. Although such studies would be highly desirable, we did not expect most of the evidence base to fall into this category.

Figure 2 Analytic Framework for Key Questions 1 and 2

a Includes deployed and non-deployed, and various eras of service

Figure 3 Analytic Framework for Key Questions 3 and 4

a Engagement in VHA services included use of any VHA benefits or specific categories of services (eg, mental health care), as defined by authors of articles.

Below, we provide our 4 key questions, and a summary of these questions in PICO format. In Key Questions 3 and 4, we use the terms “engaged” and “non-engaged” to describe groups of Veterans who differ according to enrollment in VHA or other VA benefits and services, or utilization of categories of VHA services (eg, mental health or other specialty care).

### Key Questions

Key Question 1: How do Veterans compare to non-Veterans in prevalence and characteristics of social determinants of health?

Key Question 2: Does variation in social determinants of health account for differences in health services access, health-related behaviors, and health outcomes between Veterans and non-Veterans?

Key Question 3: How do engaged (ie, enrolled in or utilizing categories of VHA services or benefits) Veterans compare to non-engaged (ie, not enrolled in or utilizing VHA services or benefits) Veterans in prevalence and characteristics of social determinants of health?

Key Question 4: Does variation in social determinants of health account for differences in health services access, health-related behaviors, and health outcomes between engaged Veterans and non-engaged Veterans?

### PICO

Population: Adult Veterans and non-Veterans

Intervention, Comparator: Not applicable

Primary Outcome: Prevalence and differences in social determinants of health

Secondary Outcomes: Differences in health services access, health-related behaviors, and health outcomes, as related to differences in social determinants of health

## SEARCH STRATEGY

We undertook a multi-faceted approach to identifying published articles that may be relevant to our key questions. First, we searched MEDLINE (OVID), the Cumulative Index to Nursing and Allied Health Literature (CINAHL), PsycINFO, and Sociological Abstracts, from the date of inception for each database to January 2017, for English language publications. Full database search strategies are presented in Appendix A. To these search results, we added references suggested by experts and peer reviewers. To assess our search results, and also to explore grey literature sources (eg, white papers) that may contribute to the evidence base, we undertook an evaluation of publications associated with multiple large national cohorts (eg, American Community Survey, Behavioral Risk Factor Surveillance System), and some VA research programs. We first reviewed whether our database search results included articles that used data from these cohorts. Then, we screened citations/abstracts and reports that were associated with these cohorts, as indicated by publication lists, bibliographies, or other available information. We applied this same process to articles and other publications associated with the VA Epidemiology Program and the National Center for Veterans Analysis and Statistics. In general, we did not identify robust sources of evidence in the grey literature that substantially added to our original search focused on peer-reviewed journal articles. Finally, in addition to the database searches and evaluation of publications associated with large national cohorts, we also completed an expedited review of citations found through a MEDLINE search with the terms as noted above (Appendix A), except using “trials” instead of selecting for other study designs. We thought it unlikely that randomized controlled trials or controlled clinical trials would address our key questions regarding the social determinants of health, but for completeness, we carried out this additional search.

## STUDY SELECTION

Citations/abstracts identified as potentially eligible by at least one reviewer underwent dual-review of the full texts. At the full-text review stage, 2 reviewers needed to agree on eligibility. Discrepancies were resolved by discussion or a third reviewer. Citation/abstract screening, full-text review, and data abstraction were performed in DistillerSR, (Evidence Partners; https://www.evidencepartners.com/products/distillersr-systematic-review-software/; accessed 5 July 2017).

We applied the following inclusion and exclusion criteria:

### Inclusion Criteria

1. Includes data on:
  a. US Veterans and non-Veterans
    and/or
  b. US Veterans engaged and not engaged in VHA services (NOTE: we use engaged and not-engaged for comparisons of groups of Veterans based on enrollment in VHA or other VA benefits and services, or utilization of categories of services [eg, mental health or other specialty care])
2. Includes at least one social determinant of interest (eg, employment, education, income, family/social support, past trauma exposure, rural residence, gender identity, or sexual orientation). For trauma, we required an independent assessment of trauma exposure; measurement of symptoms and clinical conditions presumed to be related to trauma was not sufficient. We also added new social determinants as they arose in the identified articles.

### Exclusion Criteria

1. Fewer than 100 participants
2. Does not report prevalence, degree, levels, or characteristics of social determinants by population of interest (ie, Veteran/non-Veteran, engaged/non-engaged)
3. Not study design of interest (eg, narrative review, case report, editorial/viewpoint)

Since our goal was to identify evidence that could address the role of social determinants in health, we required that included articles have valid comparison groups (eg, rural and non-rural participants, heterosexual and sexual minority respondents). Thus, studies that recruited all participants with a shared social determinant (eg, sexual minorities) were not considered as addressing the key questions for that social determinant. We agree that such studies focused on participants sharing a social determinant may be necessary first steps to understanding the potential roles of emerging social determinants of health, but they would not provide sufficient evidence to rigorously examine our key questions.

## DATA ABSTRACTION

We undertook a 2-tiered approach to: 1) provide evidence maps of all included articles, and 2) abstract detailed results for articles addressing 3 high-priority social determinants (ie, rurality, trauma, and sexual orientation or gender identity), per our discussions with our VHA partners (subsequently referred to as the 3 high-priority social determinants). For selection of these social determinants, we presented our VHA partners with preliminary evidence maps for KQ1/2 and KQ3/4, which described the number of included articles which addressed specific social determinants and any outcomes of interest.

For all included articles, we abstracted study characteristics (eg, cross-sectional or cohort design), social determinants addressed, and whether the article examined the role of social determinants in health services access or utilization, health behaviors (eg, substance use), or health outcomes of interest (eg, mental health conditions, disability). Next, for articles which investigated one of the 3 high-priority social determinants, we further abstracted the data source (eg, NHANES), participant number and demographics, measures of social determinant(s), and the prevalence, degree, or level of social determinant(s) for the groups of interest (ie, either Veterans and non-Veterans or engaged and non-engaged Veterans). If articles examined the role of social determinants in health services access, health-related behaviors, and/or health outcomes, we also abstracted methods and results from these analyses. This detailed data abstraction was completed by one reviewer with verification by a second reviewer. Discrepancies were resolved by discussion.

## QUALITY ASSESSMENT

We performed dual-reviewer quality assessment for included articles which addressed the 3 high-priority social determinants (ie, rurality, trauma, and sexual orientation or gender identity). We considered the following elements related to study quality:

1. Representativeness and coverage (ie, source of data [eg, nationally representative cohort], recruitment and selection of participants, concerns about missing data)
2. Measurement (ie, social determinants assessed in similar manner for groups being compared and using standardized measures; health-related behavior, health services access, and health outcomes assessed in similar manner for groups being compared and using standardized measures)
3. Funding source (ie, potential for bias).

Each reviewer independently rated the study quality with regard to assessment of prevalence (Key Questions 1 and 3) and with regard to examining the role of social determinants in health services access, health behaviors, or health outcomes (Key Questions 2 and 4). Discrepancies in quality ratings were resolved by discussion.

## DATA SYNTHESIS

We provide 2 separate evidence maps of included articles which addressed social determinants for Veterans and non-Veterans (KQ 1 and 2), and for Veterans engaged and not engaged in VA services and benefits (KQ 3 and 4). We use heat maps to summarize information about the number of articles reporting on various social determinants and the role of social determinants on health services access, health behaviors, or health outcomes.

For articles examining the 3 high-priority social determinants, we undertook qualitative syntheses, as described in the text and detailed tables in Appendix C.

## RATING THE BODY OF EVIDENCE

For the 3 high-priority social determinants of rurality, trauma, and sexual orientation or gender identity, we assessed overall strength of evidence as guided by the method described by Owens et al.^12^ Strength of evidence was rated as high, moderate, low, or insufficient. We based our rating on precision (degree of certainty in estimates), consistency (direction of differences across included studies), directness (whether evidence links social determinants directly to outcomes of interest), and quality rating of the individual studies (as described above).

## PEER REVIEW

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewer comments and our responses are presented in Appendix B.