# INTRODUCTION

Social determinants of health are broad and often defined in the context of other factors that also impact health. For example, the Institute of Medicine's (IOM) report, Capturing Social and Behavioral Domains and Measures in Electronic Health Records, defined social determinants as “sociocultural, socio-economic, and socio-demographic status; biosocial interactions; and the various levels of social context…”^1^ This IOM report differentiated social from behavioral factors in that the latter indicate observable actions, underlying cognitions, and/or other related psychological constructs. Similarly, Tarlov's framework posited “social and societal characteristics” as one of 5 major categories of determinants of population health, with the others being genes and biology, health behaviors, medical care, and the “ecology of all living things.”^2^ Although exact definitions vary somewhat, there is consensus that social determinants include many distinct concepts, and taken as a whole, they substantially influence health outcomes and contribute to health disparities.^2,3,4-6^

The VHA Office of Patient Care Services—Population Health Services and Office of Rural Health (hereafter, VHA partners) requested an evidence review to examine social determinants of Veterans' health, particularly as to those social determinants which may be more important for Veterans' health outcomes (or for certain Veteran groups), as compared with non-Veterans. The goal for this evidence review was to guide VHA planning for health care services that may be influenced by, or should be targeted to social determinants contributing to poorer health and greater care needs among Veterans. In collaboration with our VHA partners, we developed the scope and conceptual framework for an evidence map, with the focus being social determinants that may be differentially important for Veterans compared with non-Veterans, or between Veterans enrolled in or utilizing certain VHA services, compared with those Veterans who did not. An evidence map is a scoping review that describes key characteristics of existing, published evidence for a broad area of medicine and health.^7,8^ Given our goals focused on Veterans, our evidence map did not seek to identify and review the evidence for all social determinants of health, irrespective of populations. Furthermore, in trying to balance the extensive scope of our review with the goal of providing results that have clear implications for VHA policy and future research, we engaged our VHA partners in a prioritization process after the initial evidence map, and selected those social determinants which would undergo more detailed review and reporting of published results (ie, rurality, trauma history, sexual orientation and gender identity).