# APPENDIX C EVIDENCE TABLES

Appendix C, Table 1 Summary of Characteristics for Included Articles on Veterans and Non-Veterans

Appendix C, Table 2 Detailed Results and Characteristics of Included Articles Addressing Rurality, Trauma, and/or Sexual Orientation for Veterans and Non-Veterans

Appendix C, Table 3 Summary of Characteristics for Included Articles on Veterans Engaged and Not Engaged in VHA Services

Appendix C, Table 4 Detailed Results and Characteristics of Included Articles Addressing Rurality, Trauma, and/or Sexual Orientation for Veterans Engaged and Not Engaged in VHA Care