# APPENDIX A SEARCH STRATEGIES

## MEDLINE

1 | exp Veterans/
2 | (veteran$ or VHA or VAMC or VAHCS).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
3 | 1 or 2
4 | exp Socioeconomic Factors/ or exp “Social Determinants of Health”/
5 | (social adj2 determinant$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
6 | ((social adj2 factor$) or (behavior$ adj2 factor$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
7 | (transgender or gender identity).mp. or exp Gender Identity/ [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
8 | ((sexual adj3 minority) or sexual orientation or sexual preference).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
9 | (employ$ or unemploy$ or underemploy$).mp.
10 | exp Employment/ or job opportunities.mp.
11 | (impoverished or low-income).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
12 | exp Educational Status/
13 | (academic or occupation$ or degree or diploma).mp.
14 | (family dysfunction or child$ neglect or runaway or foster care).mp.
15 | social support.mp. or exp Social Support/
16 | exp Foster Home Care/ or foster home.mp.
17 | child abuse.mp. or exp Child Abuse/
18 | exp Life Change Events/ or adverse childhood event$.mp.
19 | Violence.mp. or exp Violence/ or exp Domestic Violence/ or exp Intimate Partner Violence/ or exp Exposure to Violence/ or exp Workplace Violence/
20 | ((trauma or violence) and (child$ or youth or adol$)).mp.
21 | exp Poverty/ or poverty.mp.
22 | exp Repression, Psychology/ or exp “Adult Survivors of Child Abuse”/ or exp Child Abuse, Sexual/
23 | (intimate partner violence or IPV).mp.
24 | exp Homeless Youth/ or exp Homeless Persons/ or homeless$.mp.
25 | exp Health Services Accessibility/
26 | (access and care).mp.
27 | exp Rural Health/ or exp Rural Population/ or exp Rural Health Services/ or rural$.mp.
28 | exp Urban Health Services/ or exp “Health Services Needs and Demand”/
29 | exp Suburban Health Services/
30 | exp Criminals/ or exp Criminal Behavior/ or (justice-involved or (justice adj involved) or (Veteran$ adj2 court) or incarcerat$ or prison or jail or recidivism).mp.
31 | (community resource$ or neighborhood or transportation or parks or mobility or livability).mp.
32 | exp Residence Characteristics/
33 | exp Environment Design/
34 | demograph$.mp.
35 | 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36 | 3 and 35
37 | exp Epidemiologic studies/ or exp case-control studies/ or exp cohort studies/ or case control.tw. or (cohort adj (study or studies)).tw. or cohort analy$.tw. or (observational adj (study or studies)).tw. or longitudinal.tw. or retrospective$.tw. or prospective$.tw. or cross-sectional.tw. or exp cross-sectional studies/
38 | 36 and 37
39 | limit 38 to english language
40 | limit 36 to (clinical study or clinical trial, all or clinical trial or comparative study or controlled clinical trial or evaluation studies or government publications or letter or meta analysis or multicenter study or observational study or pragmatic clinical trial or randomized controlled trial or systematic reviews)
41 | limit 40 to english language
42 | limit 36 to (pragmatic clinical trial or randomized controlled trial)
43 | 42 not 38

## CINAHL

S1 | AB ((social N2 determinant*) OR (socioeconomic N2 factor*) OR (social N2 factor*) OR (behavior* N2 factor*))
S2 | AB (transgender OR gender identity OR (sexual N3 minority) OR “sexual orientation” OR “sexual preference”)
S3 | AB (employ* OR unemploy* OR underemploy* OR (job N2 opportun*) OR poverty OR impoverished OR low-income OR “low income” OR academic OR occupation* OR degree OR diploma OR education*)
S4 | AB (“family dysfunction” OR (child* N2 neglect) OR runaway OR “foster care” OR “social support” OR “foster home” OR (child* N2 abuse) OR (life N2 chang* N2 event*) OR (adverse N2 childhood N2 event*) OR violence OR “domestic violence” OR “intimate partner violence” OR IPV or (exposure N2 violence) OR (work* N2 violence) OR ((trauma OR violence) AND (child* or youth or adol*)) OR homeless*)
S5 | AB ((“health services” AND (need* OR demand OR access*)) OR (access AND care) OR (access AND service*) OR rural* OR (urban AND health) OR (suburban AND health))
S6 | AB (criminal* OR “criminal behavior” OR “justice involved” OR justice-involved OR (Veteran* N2 court) OR incarcerat* OR jail OR recidivism)
S7 | AB (“community resource*” OR neighborhood OR transportation OR parks OR mobility OR livability OR residence OR (environment* W5 design) OR demograph*)
S8 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7
S9 | AB (Veteran* OR VHA OR VAMC OR VAHCS)
S10 | S8 AND S9
S11 | Limiters: Research Article: Peer Reviewed; English; Exclude MEDLINE records

## PsycINFO

S1 | DE “Military Veterans”
S2 | AB (Veteran* OR VHA OR VAMC OR VAHCS)
S3 | S1 OR S2
S4 | DE “Socioeconomic Status”
S5 | AB ((social N2 determinant*) OR (socioeconomic N2 factor*) OR (social N2 factor*) OR (behavior* N2 factor*))
S6 | AB (transgender OR gender identity OR (sexual N3 minority) OR “sexual orientation” OR “sexual preference”)
S7 | AB (employ* OR unemploy* OR underemploy* OR (job N2 opportun*) OR poverty OR impoverished OR low-income OR “low income” OR academic OR occupation* OR degree OR diploma OR education*)
S8 | AB (“family dysfunction” OR (child* N2 neglect) OR runaway OR “foster care” OR “social support” OR “foster home” OR (child* N2 abuse) OR (life N2 chang* N2 event*) OR (adverse N2 childhood N2 event*) OR violence OR “domestic violence” OR “intimate partner violence” OR IPV or (exposure N2 violence) OR (work* N2 violence) OR ((trauma OR violence) AND (child* or youth or adol*)) OR homeless*)
S9 | AB ((“health services” AND (need* OR demand OR access*)) OR (access AND care) OR (access AND service*) OR rural* OR (urban AND health) OR (suburban AND health))
S10 | AB (criminal* OR “criminal behavior” OR “justice involved” OR justice-involved OR (Veteran* N2 court) OR incarcerat* OR jail OR recidivism)
S11 | AB (“community resource*” OR neighborhood OR transportation OR parks OR mobility OR livability OR residence OR (environment* W5 design) OR demograph*)
S12 | S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11
S13 | S3 AND S12
S14 | Limiters: Publication Type: Peer Reviewed Journals Periodical; Document Type: Journal Article; English

## Sociological Abstracts

S1 | Veteran* OR VHA OR VAMC OR VAHCS
S2 | (social NEAR/2 determinant*) OR (socioeconomic NEAR/2 factor*) OR (social NEAR/2 factor*) OR (behavior* NEAR/2 factor*)
S3 | transgender OR gender identity OR (sexual NEAR/3 minority) OR “sexual orientation” OR “sexual preference”
S4 | employ* OR unemploy* OR underemploy* OR (job NEAR/2 opportun*) OR poverty OR impoverished OR low-income OR “low income” OR academic OR occupation* OR degree OR diploma OR education*
S5 | “family dysfunction” OR (child* NEAR/2 neglect) OR runaway OR “foster care” OR “social support” OR “foster home” OR (child* NEAR/2 abuse) OR (life NEAR/2 chang* NEAR/2 event*) OR (adverse NEAR/2 childhood NEAR/2 event*) OR violence OR “domestic violence” OR “intimate partner violence” OR IPV or (exposure NEAR/2 violence) OR (work* NEAR/2 violence) OR ((trauma OR violence) AND (child* or youth or adol*)) OR homeless*
S6 | (“health services” AND (need* OR demand OR access*)) OR (access AND care) OR (access AND service*) OR rural* OR (urban AND health) OR (suburban AND health)
S7 | criminal* OR “criminal behavior” OR “justice involved” OR justice-involved OR (Veteran* NEAR/2 court) OR incarcerat* OR jail OR recidivism
S8 | “community resource*” OR neighborhood OR transportation OR parks OR mobility OR livability OR residence OR (environment* PRE/5 design) OR demograph*
S9 | S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8
S10 | S1 AND S9
S11 | S10 AND stype.exact(“Scholarly Journals”)
S12 | S11 AND la.exact(“ENG”)
S13 | S12 AND at.exact(“Article’)