# SUMMARY AND DISCUSSION

## KEY FINDINGS AND QUALITY OF EVIDENCE

1. Enhanced recovery protocols significantly reduced length of stay (mean reduction 2.6 days) following colorectal surgery compared to usual care protocols (Quality of Evidence: Moderate). Length of stay reductions occurred across surgical approach (open and laparoscopic) as well as clinical indication (ie, colorectal cancer, rectal cancer, a mix of colorectal cancer and benign conditions, or benign conditions alone).
2. Enhanced recovery protocols significantly reduced overall perioperative morbidity (mean absolute reduction 10%) associated with colorectal surgery compared to usual care protocols (Quality of Evidence: Moderate). Reductions due to enhanced recovery protocols did not significantly vary by type of, or clinical condition for, surgery.
3. Mortality, hospital readmissions, and surgical site infections were similar following colorectal surgery with an enhanced recovery protocol or a usual care protocol (Quality of Evidence for Mortality: Low) (Quality of Evidence for Readmissions: Low) (Quality of Evidence for Surgical Site Infections: Low). Outcomes were similar across surgical approach and clinical indication for surgery.
4. Few studies reported on clinically meaningful differences in pain or quality of life, though most studies noted an improvement in gastrointestinal function (typically passing flatus or bowel movement).
5. Enhanced recovery protocols varied across studies, little information was provided regarding component compliance, and evidence is insufficient regarding key components.
6. Commonly reported barriers to implementation include time, resources and acceptability/feasibility of protocols to clinical staff and patients. Facilitators include organizational support, sufficient staff and electronic medical record resources, clear communication that is receptive to staff/patient feedback, and standardized yet adaptable and feasible protocols.

## DISCUSSION

Our review of 25 RCTs and CCTs (with 28 comparisons of enhanced recovery and standard care protocols) found moderate quality evidence of significantly reduced length of stay and overall morbidity in enhanced recovery protocol groups compared to standard care protocol groups. Mortality, readmissions, and surgical site infections were similar in the 2 groups (low quality evidence). Among other outcomes assessed, measures of gastrointestinal function (eg, time to first oral solid foods, flatus, and first bowel movement) were improved with enhanced recovery protocols compared to standard care protocols. Ileus, other surgical complications, and non-surgical complications were similar. Few studies reported on clinically meaningful change in pain or quality of life scores. Results were similar for open surgery and laparoscopic surgery and regardless of colorectal condition. We found insufficient evidence on whether the effects of enhanced recovery protocols vary by components, whether certain components are essential, or if certain components are unnecessary and perhaps burdensome. Our review also describes commonly reported barriers and facilitators to implementation.

Of the existing systematic reviews (Appendix A), the review by Greco et al^8^ had the greatest overlap of included studies with our review. The review was limited to RCTs published to June 2012 with no language restrictions. Sixteen RCTs were included, 5 of which were rated high risk of bias. As in our review, no significant differences were observed between the enhanced recovery group and the standard treatment group for mortality, surgical complications (limited to surgical site infections in our review), and readmissions. Overall morbidity and length of stay were significantly reduced in the enhanced recovery group compared to the control group. In the Greco review, findings were similar when only low and medium risk of bias studies were included. The number of enhanced recovery components in the included studies ranged from 4 to 13. No measure of compliance was reported and no subgroup analyses based on enhanced recovery components were performed.^8^

A critical overview of the methodology used in 10 systematic reviews and meta-analyses (to March 2013) of ERAs programs for colorectal surgery was published in 2014.^61^ Differences in study inclusion criteria (type of surgery allowed, number of enhanced recovery components), methods for meta-analyses, definitions of outcomes (particularly length of stay), handling of missing data, accuracy of extraction of data components, and reporting of key decisions in the review methodology are likely responsible for observed differences in pooled estimates across systematic reviews. The authors noted a high level of redundancy and encouraged readers of systematic reviews (particularly those seeking input for decision-making) to look for multiple reviews and to assess the quality of the review as one means of understanding differences in findings between reviews.

## IMPLICATIONS FOR PRACTICE

Few studies addressed compliance with the enhanced recovery protocols.^62^ Only 4 of the trials included in our review addressed fidelity to the ERAs protocol.^29,34,42,50^ Only one related adherence to critical outcomes.^42^ Our analysis of studies with higher differentiation or lesser differentiation of enhanced recovery protocols from standard care protocols found results similar to the overall pooled estimates with no interaction for the subgroup analysis for either length of stay or overall morbidity.

Representative data from recent observational studies (not systematically reviewed) suggest that outcomes vary depending on compliance with the enhanced recovery protocol.^63-66^ A Canadian study included 347 patients, 66% with cancer, who underwent bowel resection.^64^ A laparoscopic approach was used in 72%. The enhanced recovery protocol included 23 components, each with defined criteria for adherence. Adherence to the individual components ranged from 26% to 100% with only 2 components less than 50%. Patients were adherent to a median of 18 components (range 16-20). Adherence was significantly associated with successful recovery, a composite outcome with length of day 4 days or less, no 30-day post-operative complications, and no hospital readmissions (OR 1.39 [95% CI 1.24, 1.57] for every additional protocol component). Adherence was inversely associated with length of stay. A study from Poland with 251 patients who underwent laparoscopic resection for colorectal cancer under a 16-item enhanced recovery protocol created 3 groups of patients: those with >90% compliance (defined as “interventions fulfilled”), those with 70-90% compliance, and those with <70% compliance.

Length of stay was significantly lower (mean of 4.5 days) in the >90% compliance group than in the <70% compliance group (mean of 7.8 days).^65^ A multi-nation database (Europe and New Zealand) with over 2,300 patients who underwent resection for colorectal cancer included data on compliance with 13 enhanced recovery components. Compliance was inversely associated with length of stay (median of 6 days with greater than 90% compliance; median of 8 days with less than 50% compliance) and development of complications (33% of those with greater than 90% compliance; 48% of those with less than 50% compliance).^63^ An analysis of data from over 4,300 colorectal surgery patients in the UK found a weak but significant inverse correlation between length of stay and compliance with 19 enhanced recovery components (r=-0.18, P<.001).^66^ The median length of stay was 7 days if compliance was 70% or higher and 9 days if compliance was less than 50% (P<.001).

Furthermore, although observational studies have attempted to identify key components or subsets of components (see, for example, Loftus et al,^67^ Pecorelli et al,^64^ ERAS Compliance Group 2015^63^) there is no consensus on how many, or which specific, components are necessary to implement to achieve improved patient outcomes. There may be a specific “bundle” of practices that would improve care and patient outcomes, a concept identified by the Institute for Healthcare Improvement to describe an approach to reduce variation in practice, develop a collaborative environment, and ultimately improve outcomes.^68^

Only one of our included trials reported cost data.^32^ The study was done in China with all patients undergoing open surgery for colorectal cancer. The total cost of the procedure was $2,441 per patient in the enhanced recovery protocol group and $2,711 per patient in control group (P<.001). The postoperative expenses were $548 per patient in the enhanced recovery protocol group and $804 per patient in the control group (P<.001). The study did not provide details about what was included in the reported costs. Although not part of our systematic review, we identified one study that modeled costs of implementing an enhanced recovery program in a colorectal surgery program at The Johns Hopkins Hospital.^69^ Total first year costs were $117,875 and $552,783 for 100 and 500 cases per year, respectively or approximately $1,100 per patient. Net savings based on 500 cases per year and 1.9 day average reduction in length of stay were over $395,000. We also identified a second study from the US that reported total actual costs (including labor, supplies, and facilities) for patients undergoing colorectal surgery before and after implementation of a perioperative consult service with enhanced recovery components.^70^ Median total cost per patient decreased by 17% from pre-implementation to the extended follow-up period (5 to 14 months following implementation) (P<.05). During the same time period, median length of stay decreased from 4.2 days to 3.3 days (P<.01). Readmission and reoperation rates were not significantly different from pre- to post-implementation. The authors noted that the combination of decreased length of stay and costs achieved post-implementation meant that 4 patients could be cared for in the same time as 3 patients pre-implementation at significantly reduced cost.

Other concerns in practice include workload and sustainability of the intervention. We identified 3 studies (again, not part of our systematic review) that provide information on these topics. A study from Switzerland used a standardized point system for measuring nursing tasks associated with patient care before and after implementation of an enhanced recovery protocol.^71^ Compliance with the 21 component enhanced recovery protocol was also tracked. Nursing workload was significantly lower following introduction of the enhanced recovery protocol (point values: 61.2 before implementation, 51.6 in the year after implementation, P<.002). Relative to pre-implementation, the average time saving per patient each day was 48 minutes. There was a significant inverse correlation between nursing workload and compliance with the enhanced recovery protocol (r=-0.42, P<.001).

A study from the Netherlands reported sustainability at 3 to 5 years after implementing an enhanced recovery protocol.^72^ The analysis included data from 10 hospitals that were initially successful in implementing the protocol with success defined as length of stay 6 days or lower and protocol adherence greater than 70%. Length of stay increased from 5.25 days to 6.0 days (P>.05). Overall protocol compliance decreased from 75% to 67% (P<.01). Variation among the hospitals was noted. A study from Switzerland assessed sustainability using data from consecutive patients undergoing elective colorectal surgery at an academic hospital during the implementation process and for 3 years after.^73^ Median length of stay, readmissions, and complications (including mortality) did not differ significantly over time and were similar to pre-implementation values. Functional recovery components (day of first passage of flatus, day at which oral pain control is achieved, and mobilization of 4 hours or more on post-operative day 1) were also unchanged over the implementation and post-implementation period. Adherence to components of the enhanced recovery protocol increased from 41% before implementation to 73% during implementation and 77% during year 3. Adherence decreased significantly, however, from year 3 to year 4 (P<.05).

## LIMITATIONS

Although there is evidence from randomized controlled trials comparing enhanced recovery protocols to standard care, many studies were rated high or unclear risk of bias as methods of sequence generation, allocation concealment, and blinding were often not reported. Differences in the characteristics of the individual trials limits the interpretation and application of findings.

Observed differences in outcomes across studies might be due to implementation of different enhanced recovery protocols.^62^ In the RCTs and CCTs included in our review, we found enhanced recovery group protocols included between 4 and 18 enhanced recovery components while standard care group protocols included between 0 and 10 enhanced recovery components.

Other differences across studies include implementation of enhanced recovery in different healthcare systems and with different procedures (including discharge protocols), different patient populations (eg, exclusion of patients with ASA grades III or IV), and different outcome definitions.^62^

## APPLICABILITY OF FINDINGS TO THE VA POPULATION

None of the trials and only 2 of the qualitative studies of barriers to and facilitators of implementation were done in the US. There is no direct evidence of the effectiveness or harms of an enhanced recovery protocol for colorectal surgery in the US or at VHA facilities. Hospital length of stay, readmissions, and surgical complication rates from reported studies may not reflect US settings including those at VHA facilities. Resource needs, sustainability, or patient and provider acceptance of ERAS protocols are also not well-known. Before widely implementing an enhanced recovery protocol, discussions are needed with key staff, patients, and system groups. Although there are real potential benefits of enhanced recovery programs, particularly in reduced length of stay and possibly morbidity, rolling out a new protocol in “total quality improvement” fashion with evaluation and refinement might be the best approach due to limited applicability of existing RCT data, rapidly evolving standard practice, limited full understanding of implementation/adherence/standardization of enhanced recovery components, and possible barriers. Two recent publications describe implementation of an enhanced recovery program across multiple sites within a health care system in Canada^74^ and the US.^75^

## RESEARCH GAPS/FUTURE RESEARCH

There is a need for data from the US, and, for the purpose of making decisions relevant to Veteran care, RCTs or quality improvement program processes with real time evaluation across varying VHA facilities. While we found no empiric evidence, our key content experts and consultants suggest that many of the enhanced recovery components have been or, over time, are being adopted into standard perioperative care for colorectal surgery. A recent commentary described enhanced recovery as modern perioperative care tailored to individual patients.^76^ The author noted that some components of surgical practice are not typically included in enhanced recovery protocols including the concept of “prehabilitation.”

Studies designed to evaluate the benefits and harms of enhanced recovery protocols should provide detailed information describing enhanced recovery components and specifically how they are implemented and compliance is assessed in the intervention and control groups. Compliance should be documented for each patient with details of the anesthesiology and analgesia protocol (eg, specific medications and doses used, timing of administration), timing of pre- and post-operative solids and fluids intake, degree of mobilization, etcetera. Surgeon experience and surgical volume should be considered. Outcomes should include patient and/or caregiver experiences.^62^

## CONCLUSIONS

Implementation of enhanced recovery protocols for elective colorectal surgery resulted in reduced length of stay and overall perioperative morbidity versus standard care protocols. Mortality, readmissions, and surgical site infections were similar between the groups. However, the enhanced recovery and standard care protocols varied across studies in number of components and combinations of components with few trials reporting compliance with the protocols. There is no reliable evidence on enhanced recovery components, alone or in combination, that are key to improving patient outcomes. The value of investing time and resources into implementing all of the enhanced recovery components remains largely unknown.